# Introduction

Systematic reviews assess the comparative effectiveness and safety of health care interventions and are useful to a variety of decisionmakers. The reviews usually consider a range of outcomes that are relevant to patients and other stakeholders, and often include a variety of study designs such as trials and observational studies. Systematic reviews also attempt to identify subgroups (e.g., elderly and ethnic minorities) for which the effectiveness and harms of interventions may vary.

In certain systematic reviews, reviewers may assess benefits and harms separately, with separate key questions.1,2 Reviewers may report these results in separate tables and in separate sections of the report.3-5 The metrics used to report benefit or harm outcomes across studies are usually mean differences between study groups, odds ratios, or relative risks. Systematic reviews also tend to describe the strength (i.e., quality) of the evidence for each benefit and harm outcome separately.1 Often, the information is asymmetric, with more reliable and robust data on benefits as compared with harms. A recent review reported that only 19 percent of 104 comparative effectiveness studies of medications primarily focused on harm outcomes.6

Quantitative approaches exist to estimate the balance of benefits and harms to better inform medical and public health decisions made by stakeholders (e.g., patients or healthy subjects, health care and public health providers, payers, policymakers, or regulatory agencies such as the Food and Drug Administration or European Medicines Agency). Quantitative approaches use formulas or statistical graphs to compare benefits and harms, expressed by metrics such as an odds ratio, relative risk, or absolute difference. These quantitative approaches can combine benefit and harm outcomes on a single scale or report them separately. Some quantitative approaches also incorporate quantitative information about patient preferences. However, these approaches have primarily focused on individual studies, and some have relied on information collected from individual study participants that is unavailable to most systematic reviewers. As such, researchers have not rigorously applied these approaches to systematic reviews that synthesize information across multiple studies.

Several methodological issues are inherent to using these quantitative approaches to assess benefits and harms in systematic reviews. Systematic reviewers have rarely applied these approaches and lack guidance on how to use the approaches in systematic reviews.

Figure 1 illustrates how quantitative approaches may fit into the process of assessing benefits and harms. The process of assessing benefits and harms relies on several steps:

Step I Reporting of benefits and harms in absolute or relative terms in systematic reviews or meta-analysis;
Step II Use of quantitative approaches that provide explicit quantitative information on the benefit and harm outcomes and that may compare benefits and harms (or justification for not using a quantitative approach);
Step III Judgments made by decisionmakers^*^ at the population level after an assessment of the balance of benefits and harms; and
  * Step III involves different types of decisionmakers that may use systematic reviews to inform their decisions (e.g., guideline panels and health care payers). Depending on the decisionmaker, patient-level characteristics may require attention during population-level decisions. The choices made by these decisionmakers are likely to vary.
Step IV Shared decisions made by providers and patients at the individual level incorporating their values and preferences, often using information from decisions at the population level.

Figure 1 Stages of benefit and harm assessment

ARR = absolute risk reduction; NNT = number needed to treat; NNH = number needed to harm OR = odds ratio; QALY = quality-adjusted life years; RR = relative risk

While Evidence-based Practice Centers generally do not weigh benefits against harms when conducting systematic reviews for the Agency for Healthcare Research and Quality (AHRQ), they need to report them in a manner that makes it possible to do so. Decisionmakers need to apply valid methods to use the information in the systematic reviews for health care decisionmaking.

The specific objectives of this project were to:

1. Describe the challenges of quantitative approaches for assessing benefits and harms in systematic reviews;
2. Describe methodological characteristics of existing quantitative approaches for assessing benefits and harms in systematic reviews;
3. Determine the role of values and preferences in assessing benefits and harms across each step of a systematic review (very simply, values refer to general dispositions, and preferences refer to degrees of desirability that people associated with a health state.7 We provide more detailed definitions in the section: Influence of Values and Preferences in Assessing Benefits and Harms); and
4. Formulate principles for assessing benefits and harms in systematic reviews so that decisionmakers are better able to weigh the benefits and harms (including adverse effects and burdens) for a population and for subgroups for which this balance may vary, after accounting for values and preferences.

Our scope was limited to the assessment of quantitative approaches for assessing benefits and harms in the context of evidence synthesis. We reviewed quantitative approaches that provide an assessment of the benefits and harms of health care interventions, not diagnostic tests. Theoretical and qualitative approaches are beyond the scope of this report, as are detailed methods and guidance on the conduct of systematic reviews.8,9