# Influence of Values and Preferences in Assessing Benefits and Harms

## General Considerations and Definitions

Decisions, whether at the policy or individual level, incorporate best evidence, patient information (e.g., disease severity, life-expectancy, or comorbidity), and patient preferences.9,69 This statement, derived from the Effective Health Care Program's methods guide and the work of David Sackett, makes intuitive sense in the context of systematic reviews.

Decision analysis calls for all available evidence to be used in decisionmaking. Our team posits that preferences of patients and choices of those who generate evidence, synthesize it, make policy-level decisions, and translate evidence into practice, fundamentally inform the process of finding and using “best evidence.” Preferences and choices affect every step of this process, from the generation of evidence to the application of evidence in clinical practice. Similarly, it is difficult to arrive at a benefit harm assessment based on “best evidence” without acknowledging preferences and choices. Many approaches have been used for quantitatively assessing benefit and harm in individual studies that may be relevant for evidence syntheses, such as systematic reviews and modeling tools. These approaches depend on the choices made by investigators and systematic reviewers about the incorporation of preferences.

Our team believes that we will arrive at better assessments of benefits and harms if we are explicit and transparent about the ways choices and preferences affect how we generate and synthesize evidence. For example, when trial investigators select outcomes, they implicitly make a choice that reflects what they think is important for decisionmaking. The same applies to systematic reviews, even if systematic reviewers may not always be explicit about the role of patient preferences. When systematic reviewers seek input from stakeholders (or key informants) about the key questions to address in a systematic review, the preferences of the key informants will affect this process. The key informants may have different preferences, as noted in the example of the reports on venous thromboembolism. 30,31 In these examples, pulmonary embolism was considered a clinically important outcome by both, but prevention of deep vein thrombosis was not considered clinically important by both.30,31 To make users of systematic reviews (e.g., payers and guideline developers) aware of the role that choices and preferences play in systematic reviews, it is necessary to be explicit about the rationale for the decisions that were made in designing and conducting each review. In addition, to optimally assess and present data on benefits and harms, systematic reviewers should consider how end users interpret these systematic reviews.

Our objective in this section is to describe how preferences and choices play a role in various approaches to assessing the benefits and harms of interventions. The team reports its findings according to four stages of the process of translation: (1) evidence generation (e.g., RCTs and observational studies); (2) evidence synthesis (e.g., systematic reviews and meta-analyses); (3) processes used in moving from evidence generation to development of evidence-based medicine tools (e.g., modeling or simulation based on a decisionmaking context); and (4) the generation of evidence-based medicine tools (e.g., clinical practice guidelines and decision aids). We chose this organizational scheme because it is important to consider the full continuum of areas where preferences and choices may influence systematic reviews and quantitative approaches to assessing the benefits and harms of interventions.

### Definitions

Medical literature uses the terms “patient preferences” and “patient values” together or interchangeably in the area of benefit harm assessment. Often, the literature does not adequately define these terms and the difference between values and preferences is not clear.70

The Journal of the American Medical Association (JAMA) user's guide to the medical literature defines patient preferences and values as: “an overarching term that includes patients' perspectives, beliefs, expectations, and goals for health and life. We (JAMA) also use this phrase, more precisely, to mean the processes that individuals use in considering the potential benefits, harms, costs, and inconveniences of the management options in relation to one another.”70

As has been done by others,7 we believe distinguishing between values and preferences is useful. For purposes of this discussion, we have distinguished between patient values and patient preferences, as defined below, and we have added consideration of the choices that are made by decisionmakers when assessing benefits and harms of medical interventions (see Figure 4, Preferences and choices influencing decisionmaking at the policy level). This report refers predominantly to patient preferences and decisionmaker choices according to the working definitions given in the text below.

Figure 4 Preferences and choices influencing decisionmaking at the policy level^a^ a As this report is focused on decisionmaking at the population level, we have not included providers of clinical care in this figure, although clinical providers are likely to have important roles in research, evidence synthesis, and policymaking. This figure does not represent individual level decisionmaking.

### Patient Preferences

Patient preferences express the relative importance that patients or potential patients place on various health outcomes. They refer to the degrees of subjective satisfaction, distress, or desirability that patients or potential patients associate with a particular health outcomes. The various health states can be different severities of one condition (e.g., mild vs. moderate vs. severe dyspnea) or different conditions (e.g., hospital admission vs. severe dyspnea). Preferences are a consequence of values and beliefs and the specific contexts in which patients face decisionmaking. Utility instruments can both elicit and express preferences.

### Patient Values

Values are a person's beliefs, desires, and expectations of what is right or wrong. Studies generally base values on predispositions as well as on family and cultural context and experiences. Values are latent traits that are not directly observable (i.e., measurable). Studies can only approximate values by how people express them (e.g., through preferences). Values are not specific to a certain context.

### Decisionmaker Choices

Multiple decisionmakers may be involved in benefit and harm assessment, as described in Figure 4, including: investigators for clinical trials and observational studies (hereafter referred to as investigators); systematic reviewers; policymakers such as payers and guideline developers; and ultimately, both clinicians and patients. Importantly, for stages I to III of benefit harm assessment, (described earlier in this report in Figure 1) clinician (provider) preferences may also factor in through their roles on guideline panels and regulatory bodies. End users of systematic reviews are typically policymakers and other decisionmakers, but may also include clinicians.

Ideally, all of these decisionmakers have patients as their primary focus and therefore care about patient preferences, but decisionmakers may need to make decisions in the absence of perfect information.71 This is one of the reasons why minimizing conflicts of interest, or at least openly declaring them, is so important for benefit harm assessment.72 Since patient preferences are often not available, these decisionmakers must operationalize what is known (or assumed to be true when evidence about patient preferences and their variability is lacking) about patient preferences, and they may incorporate other types of information into their choices as well. These include perceptions about societal preferences as well as recognition of varied preferences among specific subgroups.

Increasingly, the health care community is encouraging policymakers, such as guideline developers, to be explicit about the role that assumptions about patient preferences play in the process of issuing recommendations in practice guidelines.26,73,74 Decisionmaker choices are important, and should be both explicit and transparent. For example, financial considerations might influence choices that trial investigators make about specific outcomes to measure. Similarly, investigators make choices regarding length of the study, outcomes followed, and eligibility criteria of a trial. For clarity, this report uses the term “investigator choices” to describe choices made by investigators that are informed by both patient preferences and other considerations. Similarly, we use the terms “systematic reviewer choices” for choices made by reviewers that are informed by the preferences of patients and other considerations, and “policymaker choices” for choices made by policymakers that are informed by the preferences of patients and other considerations.

## Role of Choices and Preferences in Benefit Harm Assessment

### The Role of Choices and Preferences in Evidence Generation

Investigator choices influence evidence generation in randomized controlled trials and observational studies in several ways. The choices are often implicit, and may or may not directly account for patient preferences.

Using the Population, Intervention, Comparator, Outcome, Timeframe, and Setting (PICOTS) framework, our team first looked at the many ways investigator choices affect study design. For example, investigator choices affect decisions regarding the definition of a study population, in terms of eligibility criteria and the aggressiveness with which the study recruits older, complex, or otherwise vulnerable populations. Investigator choices also influence decisions regarding the intervention to be tested, the length of the study, and the comparator(s).

Investigator choices also affect decisions regarding the selection of outcomes to be assessed in a clinical trial or observational study. For example, what is the primary outcome, and what are secondary outcomes? To consider the patient's perspective, investigators should choose outcomes important to patients (e.g., mortality or function) as primary outcomes, but in many cases researchers choose an intermediate, or surrogate, outcome for reasons of feasibility (e.g., short-term trials, smaller sample sizes). How closely linked surrogate outcomes are to health, or patient-important, outcomes varies by condition as well as by specific types of treatment, and often evidence is insufficient to appraise this linkage.23,71,75 For example, to validate surrogate outcomes of oral agents for type 2 diabetes (e.g., glycated hemoglobin), systematic reviews should appraise the linkage between glycated hemoglobin and cardiovascular outcome separately for each drug class (such as metformin and thiazolidinediones).23 The evidence that metformin lowers glycated hemoglobin and potentially reduces cardiovascular risk does not validate the use of thiazolidinediones to lower cardiovascular risk. Even though thiazolidinediones also lower glycated hemoglobin, similar to metformin, they may have a neutral or even adverse effect on cardiovascular outcomes.76 Therefore, critical choices need to be made by investigators. Investigator choices also affect how study procedures account for outcomes that may be unintended consequences (such as harms).

Our team also looked at how investigator choices influence decisions regarding the analysis of a study. For example, investigator choices influence decisions regarding whether and how to assess for heterogeneity of treatment effects across study subpopulations. Investigator choices may also determine: (1) whether investigators conduct a quantitative benefit harm assessment and which outcomes enter such an assessment, (2) whether investigators use intention–to-treat or per-protocol analysis, (3) how rigorously investigators will ascertain data on harms, and (4) how frequently they will collect data on harm from participants who withdraw from the study. Participants may withdraw because of harms, and not counting these participants may result in the under-ascertainment of harms.77

### The Role of Choices and Preferences for Evidence Synthesis

When synthesizing evidence, systematic reviewers attempt to incorporate different perspectives by soliciting input from diverse stakeholders or technical experts (e.g., generalist physicians, specialists, and patient representatives). These diverse inputs are implicitly assumed to provide information about the variability of preferences and values, but this is often an unverifiable assumption.

“Patient preference” was only introduced as a Medical Subject Headings term in PubMed in the year 2010, and the underlying information base for patient preferences is still evolving.78 Thus, few evidence reports mention an explicit search for information on patient preferences. For example, in contrast to the large number of studies that reported on the effectiveness of medications for type 2 diabetes, very few studies are available on the role of patient preferences in weighing various outcomes in type 2 diabetes.

In evidence syntheses, systematic reviewers and the stakeholders they choose to engage make choices on the basis of implicit assumptions about preferences. The choices affect each component of the PICOTS framework for defining key questions. The decisions are parallel to those described in this report under “evidence generation.” In the EPC Program, systematic reviewers make these decisions as they develop their key questions with the input of key informants including prominent investigators. Thus, preferences and choices of investigators and other stakeholders may influence what outcomes systematic reviewers consider important in the systematic review. The preferences and choices of stakeholders may also influence the assumptions that systematic reviewers make about the relative weights of benefits and harms.

An illustrative example is the distinction between reporting number needed to treat (NNT) and number needed to harm (NNH), and reporting a NNT/NNH ratio. A NNT/NNH ratio, unless explicitly calculated using relative weights, may implicitly assume that a given benefit and a given harm are equally important, although a decisionmaker could decide to compare the ratio to something other than one. Reporting NNT and NNH separately (e.g., no ratio) does not make any assumptions about the relative importance of the outcomes. This issue is related to the way in which the reviewer puts the results in context and helps the reader interpret them. There are extensions of the NNT/NNH ratio approach that explicitly consider patient preferences, or that consider whether the approach can handle more than one outcome for benefit and harm. For additional information, refer to the section in this report on quantitative approaches.

Quantitative approaches informed by preferences may bring worthwhile information to end users of systematic reviews regarding the balance of benefits and harms. Systematic reviewers should present the results of quantitative approaches for benefit harm assessment under different assumptions about patient preferences to help decisionmakers understand the implications of varied preferences (Figure 4).

### The Role of Choices and Preferences for Processes, From Evidence Generation to Development of Evidence-based Medicine Tools: Modeling or Simulation

Modeling and simulation are important tools for assessing benefits and harms; several quantitative approaches to benefit harm assessment include these tools. These approaches all require input about preferences, in the choices of important outcomes, time horizons, and patient profiles. Modeling or simulation for a specific decisionmaking context also requires an understanding of the relative weights of benefits and harms (ideally based on patient preferences) and assumptions about whether the distributions of benefits and harms are independent.

### The Role of Choices and Preferences for Development of Evidence-Based Medicine Tools

The role of preferences in the development of guidelines and decision aids is increasingly explicit.71,79,80 The formulation of recommendations in guidelines depends on the ability of the guideline developers to reach conclusions about the uncertainty or variability of preferences on the behalf of patients. For example, if reviewers conclude that patient preferences vary only slightly and that the balance of benefit and harm favors benefits, guideline developers are likely to issue a strong recommendation if it is also supported with high-quality evidence. Uncertainty or variability in values and preferences may lead to a weak recommendation.26

Understanding when patient preferences vary is therefore important for determining the strength of the recommendation in guidelines. Decisionmakers often have imperfect information about patient preferences, but nevertheless must arrive at a decision that incorporates perceived preferences. Thus, decisionmakers must make inferences about patient preferences that are, in turn, incorporated into the decisionmaking process. This role contributes to an emerging consensus about the necessity to minimize conflicts of interest and to ensure that the leadership of guideline panels includes those without conflicts of interest. A conflict of interest in this case would be a situation in which a decisionmaker could benefit from a recommendation that is not reflective of patient preferences.

Similar issues affect decision aids.81 To create useful decision aids, decisionmakers must identify (early in the development process) the appropriate clinical situations where preferences affect decisionmaking. For example, decisionmakers need to recognize how patients view the effects of urinary incontinence on their quality of life and incorporate preferences regarding this outcome into a decision aid about treatment options.82

### Use of Evidence-Based Medicine Tools in Clinical Practice

Clinical decisionmakers must combine individual patient preferences with guideline recommendations and decision aids. Population-level decisions, such as those made to inform coverage or guideline recommendations, will not be identical to every individual's decision, because both the context of individual decisions and the preferences of individuals may be different.83 This is true even in settings with individual patients having shared decisionmaking using high-quality, applicable evidence regarding the likelihood of benefit and harm. This difference is due primarily to the variation in the relative weights patients would apply to the different possible outcomes, including benefits and harms. Modern decision aids often include an instrument to elicit preferences and to make suggestions to patients that are based on their own preferences.84

Patient preferences may affect decisionmaking to varying degrees. Most health care decisions are preference-sensitive, especially in the context of chronic diseases.85,86 Preference-sensitive decisions are made in situations where different decisionmakers may reach different conclusions based on their personal preferences for what is known about the benefit and harm. For example, Protheroe et al. showed that patient preferences have a strong effect on whether or not guideline-concordant care is selected for the prevention of stroke from atrial fibrillation with aspirin or warfarin.83 Similarly, Sussman et al. demonstrated that patient preferences have a large impact on whether or not aspirin would be recommended for the primary prevention of myocardial infarction or stroke.87 Exceptions occur when preferences do not play much of a role because of unambiguous evidence that a certain health intervention is virtually always necessary. Examples would be surgical repair of ongoing bleeding, displaced fracture due to trauma, or antibiotic treatment of a child with sepsis.