# Discussion

In the pages that follow, we discuss the key findings for each of our objectives. We then discuss the limitations of this report, identify future research needs, and summarize our overall conclusions.

For Objective 1, we found a number of challenges related to the conduct of a systematic review, the grading of the strength of evidence, and the incorporation of preferences in a review.

First, benefit and harm, or uncertainty about the balance between the two, may vary for subgroups of the population. Assessment of benefit and harm may depend on the linkages between surrogates and health outcomes for specific interventions, and whether these linkages vary across subgroups. The time horizon for studying benefits and harms may be inadequate in many studies included in a review. In addition, the fidelity with which the intervention was applied may vary across studies, making a synthesis of benefits and harms difficult.

Another significant challenge is to judge the applicability of studies to the target population of interest with respect to both benefits and harms. Studies may be designed to provide more robust data on benefits than on harms, requiring the assessment of harms through study designs other than randomized controlled trials (RCTs), such as observational studies or case reports. When such information asymmetry exists, the strength of evidence will vary for different benefits and harms, making it difficult to rate the strength of evidence for the overall balance of benefits and harms.

Using a quantitative approach for assessment of benefits and harms may require several assumptions. Data are usually unavailable on the joint distribution of benefits and harms under various scenarios, and it may vary among different patient profiles. Benefits and harms may be reported on different scales. Values and preferences affect how people weigh the relative importance of benefit and harm outcomes. Such data on values and preferences are usually unavailable to systematic reviewers.

In Objective 2, we described the methodological characteristics of existing quantitative approaches for assessing benefit and harm. The main findings of our review of the available quantitative approaches for assessing benefits and harms using a unifying framework are summarized below.

1. Existing quantitative approaches can be categorized into approaches that consider single or multiple benefit and harm outcomes as well as those approaches that use or do not use a benefit and harm comparison metric.
2. Although none of the approaches seemed to be developed specifically for handling aggregate data in systematic reviews, systematic reviews can use all quantitative approaches except for benefit-less-risk analysis, Boers' method, and stated preference method or maximum acceptable risk, all of which require individual patient data that may include data from randomized trials (benefit-less-risk analysis) but also data from preference-eliciting surveys.
3. None of the quantitative approaches for assessing benefit and harm explicitly consider the asymmetry in the quality and quantity of evidence, which is generally higher and larger, respectively, for benefits as compared with harms. Such asymmetry is particularly important in the context of a systematic review because it has implications for the search strategy, selection of the evidence, and the overall workload of reviewers.
4. No single quantitative approach can be favored clearly over the others in the context of every systematic review. The selection of a quantitative approach depends on the number of key outcomes, the need or desire for a benefit and harm comparison metric, the balance between offering as many of the outlined desired properties as possible and the feasibility of ascertaining a comprehensive evidence base, and the availability of epidemiological and statistical expertise. Finally, a comprehensive benefit harm assessment could use a combination of the approaches reviewed here.

The team identified a number of assumptions that researchers make implicitly when applying almost any quantitative approach for assessing benefits and harms. First, for most approaches, researchers assume that one or more benefit and harm outcomes can be put on the same scale to calculate a benefit and harm comparison metric. Challenges for putting different outcomes on the same scale include their relative importance to decisionmakers (which may require different weighting), simplification of the outcomes (e.g., dichotomizing continuous outcomes, which may lead to substantial loss of information), or different methods and timing used in ascertaining different outcomes. A benefit and harm comparison metric may offer some advantages particularly in the context of situations where multiple outcomes are important and where patient, provider, and policymaker preferences vary. The advantage of using such a metric, compared to an approach without a benefit and harm comparison metric, is that researchers make explicit assumptions about the relative importance of outcomes. Sensitivity analyses can provide evidence showing how the benefit and harm balance changes if researchers make different assumptions. A single estimate may provide some advantages for the communication of net treatment benefits to patients and avoids overwhelming the patients with data on multiple different outcomes. Ultimately, decisionmakers should judge the usefulness of a benefit and harm comparison metric for the types of decisions they need to make.

Second, the use of multiple endpoints generally seems more feasible than the use of composite outcomes in quantitative approaches for assessing benefits and harms. Reviewers may assume they can build composite outcomes that provide useful information for decisionmakers. Some reviewers may see this as similar to putting different outcomes on the same scale. However, composite outcomes may not be a suitable option in systematic reviews, because benefits and harms are often defined differently across trials. Consistent composite outcomes can only be constructed if detailed data on individual endpoints are available from the primary studies. In certain instances, composite outcomes may provide misleading results.22,89

Third, the reports using these quantitative approaches did not consider the joint distribution of benefit and harm even when individual patient data were available. Uncertainty estimates for the benefit and harm comparison metric may be different if studies considered joint distributions. We did not identify studies that quantified such a difference between uncertainty estimates, with and without consideration of the joint distributions. Systematic reviews usually do not have access to information on the joint distribution of benefit and harm outcomes in the primary studies. Thus, systematic reviewers are unable to consistently report the joint distribution of benefit and harm outcomes across studies. However, systematic reviewers should consider that ignoring the joint distribution when interpreting results from a quantitative benefit harm assessment could present a significant limitation.

If systematic reviewers decide to conduct a quantitative benefit harm assessment, they may choose among the approaches presented in this report, or combinations thereof and among others outside our scope, like decision analysis. Furthermore, it is likely that additional quantitative approaches are currently being developed or that existing approaches are being modified. Feasibility is obviously one of the factors that will drive the decision on which approach to choose. Relatively simple quantitative approaches include number needed to treat (NNT) and number needed to harm (NNH), NNT/NNH ratio and its modifications, minimum clinical efficacy, and transparent uniform risk-benefit overview. Other more complex quantitative approaches may be difficult to apply in most systematic reviews, such as incremental net health benefit, net clinical benefit, probabilistic simulation method, multicriteria decision analysis, or Gail/NCI (National Cancer Institute) because they require information that systematic reviews don't collect automatically, and epidemiological and statistical expertise that may not be available.

It is important to clearly define the decisionmaking context of a systematic review. This includes a characterization of the decisionmakers that need to be informed and their need to solve decisional conflicts. Defining the decisionmaking context helps define the exact research question, the eligibility criteria for studies and aspects of study design, and the quantitative approach for assessing benefit and harm that will fulfill as many of the desired properties as possible. As a result, it may be that for some decisionmaking contexts, available RCTs provide all the evidence needed and one of the simpler approaches for quantitative benefit harm assessment fulfills important desired properties. If the number of benefit and harm outcomes becomes larger, the time horizon longer, and the patient population more heterogeneous, it is likely that only one of the more complex approaches will provide a quantitative benefit and harm assessment that fulfills the described properties and meets the decisionmakers' needs.

Since none of the approaches are perfect and all require some assumptions, sensitivity analyses are important. When using a specific approach it may be wise to specify the assumptions made for the main analysis and to assess how the results change if the assumptions are modified.

Also, it may be valuable to consider additional approaches to assess whether the results and conclusions from a benefit harm assessment depend on the strengths and limitations of the specific quantitative approach used. An additional important consideration for systematic reviewers is that some of the approaches reviewed here may be combined. For example, NNT and NNH, as well as some of the visual approaches such as risk-benefit contour, could be used to present the results in a multicriteria decision analysis. Alternatively, simulation could be used if the study did not assess the benefit and harm outcomes in the full range of the population that clinicians might consider treating.

For Objective 3 we discussed the influence of patient values and preferences, as well as decisionmaker choices, in assessing benefits and harms across each step of a systematic review and the process of translation before and after systematic reviews. Choices and preferences affect benefit harm assessments across the entire path of evidence translation: evidence generation (e.g., RCTs and observational studies); evidence synthesis (e.g., systematic reviews and meta-analyses); processes used in moving from evidence generation to development of evidence-based medicine tools, such as modeling or simulation based on a decisionmaking context; and the generation of evidence-based medicine tools (e.g., clinical practice guidelines, decision aids). In current practice, choices are often implicit and not transparently reported in many of these steps. For systematic reviewers, this is true whether reviewers simply report on the benefits and harms, or use quantitative approaches to assess the benefits and harms. Thus, deciding not to use quantitative approaches does not mean that choices are not relevant. Choices and preferences also affect how guideline developers frame recommendations, how regulatory bodies make decisions at the population level, and how clinicians, patients, and other end users make decisions at the individual level.

For Objective 4, we formulated principles for assessing benefits and harms in systematic reviews that relate to protocol development or conduct and reporting. Because no method is clearly superior to others for conducting an assessment of benefits and harms in a systematic review, the principles generally emphasize the need to report not just results but also to describe how decisions were made. We emphasized the need to report which assumptions related to chosen methods are likely to be critical. Since benefit harm assessments are highly multidimensional, there will always be some arbitrary decisions involved in the assessments. Sensitivity analyses are therefore important to quantify the effect of arbitrary decisions on the results of quantitative benefit harm assessments.

Estimating uncertainty is also important for decisionmaking. Also, it is critical to preserve information while reporting on benefits and harms to assess variation in benefit harm assessment across relevant subgroups. As is recommended in the Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews, to overcome information asymmetry the assessment of harms in systematic reviews should not be restricted to specific study types.9 While observational studies provide important information on harms associated with certain treatments, they are more susceptible to confounding, selection, information and reporting bias than RCTs.

## Limitations

We understand that this report has several limitations. We reviewed a small sample of evidence reports, so it is possible that we did not identify all the relevant challenges. The sample of evidence reports we reviewed was illustrative of the major challenges facing systematic reviews in conducting a benefit harm assessment.

Since we did not conduct a systematic review, we may have missed some quantitative approaches to benefit and harm assessment. We reviewed the most commonly used approaches so it is possible that we did not identify all characteristics of benefit harm assessments that could be applied to a systematic review. We did not evaluate quantitative methods that researchers have used outside the health care setting. Decision trees and influence relevance diagrams may require data beyond what is typically available from evidence generated from a systematic review and were beyond the scope of this project. We did not evaluate the full range of other decision analytic approaches that use principles of risk analysis, mathematical psychology, evaluation sciences, and conjoint measurement theory. Our principles are not prescriptive and cannot address all the challenges of benefit harm assessment, which fall outside the domain of systematic reviews.

## Future Research

Further empirical work is needed to improve understanding of the utility of different quantitative approaches for assessing benefits and harms in systematic reviews. Such work should assess the value of the quantitative approaches from the standpoint of decisionmakers. For example, what metrics of benefits and harms are most relevant and useful to various types of decisionmakers? How do decisionmakers feel about the desirability of combining multiple outcomes into one metric when the clinical intervention has a complex set of benefits and harms? How important is it to use metrics that incorporate preferences? How important is it to use metrics that are transparent about potential uncertainty? As methods continue to evolve for assessing and reporting on the balance of benefits and harms, it will be necessary to further develop the methods for conducting systematic reviews of preferences as well as for synthesizing evidence on preferences.78 It will also be necessary to give more attention to the methods for grading the strength of evidence when a quantitative approach is used to assess benefits and harms.

Future studies need to evaluate whether network meta-analysis can address some of the challenges identified above. Researchers have recently published network meta-analyses on the relative effects of alternative interventions on benefit and harm outcomes.25 The lack of evidence from direct comparisons in the context of systematic reviews of benefit harm assessments can be evaluated in network meta-analysis. Such analyses provide estimates on the relative effectiveness of health care interventions by considering both direct and indirect evidence. Studies included in a network meta-analysis should be, as in any conventional meta-analysis, comparable in terms of quality (e.g., risk of bias), applicability, and measurement of outcomes. In addition, meta-analyses should include a close examination of the consistency of results from direct and indirect evidence.90

## Conclusions

A number of quantitative approaches for benefit harm assessment are available for systematic reviewers. The choice of a particular approach depends on the decision to be informed, the available data, and the epidemiological-statistical expertise of the systematic review team. Quantitative approaches may often be attractive because they enhance transparency and help decisionmakers understand the multidimensionality of benefit harm assessments. By considering the challenges of benefit harm assessments, the characteristics of available quantitative approaches, and the recommended principles for using a quantitative approach, systematic reviewers should be able to choose an approach that will enhance their assessment of the balance of benefits and harms in each review.