# Challenges of Quantitative Approaches for Assessing Benefit and Harm

The challenges in assessing benefits or harms in systematic reviews are listed below and shown in Table 1. The team organized its listing of challenges around the Population, Intervention, Comparator, Outcome, Timeframe, and Setting (PICOTS) criteria,9 with some minor adaptations to incorporate the challenges of preferences.

Table 1 Summary listing of challenges in assessing benefits and harms in systematic reviews

Criteria | Challenges
Populations | Benefits and harms, or uncertainty about the balance between them, may vary for subgroups of the population.
Interventions | Benefits and harms may vary due to differences in the fidelity of interventions across studies.
Comparisons | The estimates of effect from a study may reflect the beneficial effect of one intervention or the harmful effect of a comparator.
Outcomes | Assessment may depend on the linkages between surrogates and health outcomes for specific interventions and whether there is variation in these linkages across subgroups. Assessment may also depend on composite outcome measures, where individual elements of the composite measure may have different effect sizes and a different gradient of preferences.
Time Horizon | The time horizon in studies may be inadequate for assessing all benefits and harms (e.g., early benefit, late risks)
Study Designs | Studies may be designed to provide more robust data on benefits than on harms. Assessment of harms may require study designs other than RCTs, such as observational studies or case reports.
Strength of Evidence | The strength of evidence may vary for different benefits and harms, making it difficult to rate the strength of evidence for the balance of benefits and harms.
2Data | Data may be lacking on the joint distribution of benefits and harms under various scenarios.
Scale of treatment effect | Benefits and harms may be reported on a relative or absolute scale. Systematic reviewers should conduct the quantitative assessment of benefits and harms on an absolute scale or use both absolute and relative scales.
Preferences | Values and preferences affect how people weigh the relative importance of outcomes. End users may perceive the incorporation of values and preferences in benefit harm assessments as the equivalent of making treatment recommendations.

RCTs = randomized controlled trials

## Challenges With Regard to the Research Question

### Populations

When assessing benefits and harms in systematic reviews, systematic reviewers face the challenge of determining whether the evidence on benefits and harms is applicable to the target population of interest. Systematic reviewers generally limit the inclusion of studies based on the characteristics of the study populations. The applicability of evidence to particular subgroups of interest (e.g., older or comorbid population) may be different for benefits than for harms. For example, the premarketing trials of the cyclo-oxygenase-2 inhibitors provided evidence of benefit in selected samples of patients with arthritis.18 However, these trials excluded patients with comorbid cardiovascular disease. Subsequent studies demonstrated that cyclo-oxygenase-2 inhibitors increased the risk of serious adverse cardiovascular events, particularly in high-risk populations.18

Another challenge is that the ultimate balance of benefit and harm, as determined by decisionmakers, may vary for subgroups defined by specific characteristics among the population (e.g., age, or presence of comorbidity) or by estimated risk of adverse outcomes (e.g., <5, 5–10 or >10 percent risk for 10-year mortality). The reason for such variation may include the altered pharmacodynamic or pharmacokinetic properties of drugs with age. For example, a drug that is cleared by the kidneys and toxic at higher doses may accumulate in older populations and have a different benefit and harm profile than in younger populations.

### Interventions

A systematic review may include studies with varying degrees of fidelity to the intervention. Fidelity is the extent to which patients in the study receive the same prestated intervention.19 Lack of fidelity in the interventions may make it difficult for a systematic reviewer to interpret differences between studies in the reported benefits and harms. Measures of intervention fidelity include the adherence to the components delivered, exposure or dose of the intervention, quality of delivery, participant responsiveness, and uniqueness of the intervention.20 The fidelity of the intervention to a prespecified protocol may vary between studies that report on benefit or harm.

### Comparators

Another challenge is assessing whether the estimates of effect from active controlled trials reflect the beneficial effect of one intervention or the harmful effect of another. The efficacy of a pharmacologic intervention is often established in placebo-controlled randomized controlled trials (RCTs) that are required for regulatory approval.12 The estimates of benefits and harms may vary based on the comparators used in RCTs, such as placebo or active controls. Estimates of treatment effect from active controlled trials may either be interpreted to reflect the beneficial effect of one intervention or the harmful effect of another.18 In observational studies, comparisons of benefits and harms may also differ based on whether users of a therapeutic agent are compared with nonusers or users of other therapeutic agents. For example, when a five times higher risk of myocardial infarction was seen with rofecoxib 50 mg compared with naproxen 500 mg daily in the Vioxx^®^ Gastrointestinal Outcomes Research study, one of the initial interpretations offered was that these findings reflected the beneficial effect of naproxen rather than the harmful effects of rofecoxib.18 However, subsequent placebo controlled trials and other observational studies confirmed the cardiovascular hazards of rofecoxib and also provided evidence that naproxen offered no such cardiovascular benefit,18 and may also carry a smaller cardiovascular hazard.

### Outcomes

Systematic reviews usually consider a range of outcomes, with substantial variability and information asymmetry in the reporting of benefits and harms across studies. We generally see more reliable and more robust data on benefits as compared with harms of interventions. This may hinder an adequate assessment by decisionmakers of the balance of benefits and harms associated with the interventions of interest.21

Some systematic reviews report on composite outcomes. An assessment of the balance of benefits and harms using a composite outcome is challenging, especially if the individual elements of the composite outcome occur at different frequencies, show different effect sizes, or are of unequal clinical importance.22

Since there is no well-accepted measure of benefit across therapeutic areas, systematic reviews report on a range of surrogate and health outcomes.21 Surrogate outcomes for benefit also pose challenges for assessing benefits and harms, and may include: biochemical endpoints, such as improvement in glycated hemoglobin or cholesterol; pathophysiological variables, such as improvement in blood pressure and ejection fraction; and morphological variables, such as left ventricular hypertrophy. Health outcomes are clinical outcomes that affect how patients feel, live or survive, such as quality of life, rate of survival, and patient satisfaction, and are sometimes referred to as patient-important outcomes. We use the terms “surrogate outcomes” and “health outcomes” (from the AHRQ Methods Guide) throughout this report. 23

A recent systematic review found evidence of benefit from various oral hypoglycemic agents on the surrogate outcome of glycated hemoglobin.12 However, the review found no conclusive evidence of the benefit of these agents on cardiovascular outcomes or mortality. To conduct an assessment of benefits and harms, reviewers must determine if the surrogate has been validated for each intervention for the health outcomes in the analytic framework.23 Information may be unavailable to reviewers regarding links between surrogate and health outcomes and how these links may vary by subgroups such as older adults. Even if the surrogate is validated, it is challenging to translate the quantitative benefit of the surrogate outcome into a quantitative estimate for the health or patient-important outcome.

Studies generally prespecify and measure benefit outcomes with great reliability. This is not always true with harm outcomes, which are often unexpected and have much more variability in definition across RCTs. Unless researchers know the harms of an intervention a priori (e.g., bleeding with anticoagulants), researchers may not have a prespecified way of defining a particular type of adverse event or may include events in the category of “other adverse events.” In a recent systematic review, the outcome of congestive heart failure reported as an adverse event ranged from heart failure events that are diagnosed only based on symptoms of breathlessness to congestive heart failure requiring hospitalization that is confirmed by echocardiography.12 Systematic reviewers must assess the need for sensitivity, which increases the power to find evidence of rare harmful events, versus specificity of outcome definitions, which, in turn provides greater confidence in the strength of an association.

### Time

The time horizon in studies may be inadequate for assessing all benefits and harms (e.g., early benefit, late risks), as the balance of benefit and harm in the short term may be different from the balance of benefit and harm in the long term. Although combined hormone replacement therapy did not prevent coronary events in the Heart and Estrogen/Progestin Replacement study, further analysis suggested early harm during the first year with the possibility of late benefit during followup 4 to 5 years later.24

## Challenges With Regard to the Study Design

Well-designed RCTs provide the most valid estimates of the effect treatments have on benefits and harms, because of the control of confounding and selection bias. However, RCTs are often designed and powered to detect the effect of treatments on selected benefit outcomes, while harm outcomes receive less attention in terms of the quality of data ascertainment and statistical power. Also, some RCTs exclude patients that have certain characteristics (e.g., old age, comorbidity), associated with greater risk of harm. Some RCTs have a duration of followup that is sufficient for benefit outcomes but not for harm outcomes. In addition, RCTs may be statistically underpowered for detection of rare but potentially serious harms because of the limited size and duration of trials. The resulting asymmetry in the quality and quantity of evidence for benefit and harm outcomes from RCTs are the main reason why some systematic reviews may include observational studies as well as RCTs.25 Observational studies are an important source of information on benefit when RCTs are not long enough and/or do not include outcomes important to patients. Other nonrandomized designs, including spontaneous case reports, may provide a useful source of information on harms, particularly in the case of rare events with very low background rates in the general population. Estimates of harm from RCTs and observational studies vary due to differences in study quality, applicability (e.g., populations, interventions or comparisons), measurement of outcomes, publication bias, outcome reporting, or sources of funding.25 As a result, estimates concerning harm tend to have more uncertainty compared with estimates of benefit.

### Strength of Evidence

Systematic reviewers need to incorporate assessment of the strength of evidence when assessing the balance of benefits and harms in systematic reviews. The problem arises because systematic reviewers may grade the strength of evidence separately for each outcome of each key question.4,9,12 For example, a recent systematic review on angiotensin converting enzyme inhibitors and angiotensin receptor blockers4 presented evidence on various benefit and harm outcomes with different evidence grades.

The strength of evidence ratings for harm outcomes are more complicated than the ratings for benefit outcomes because definitions for harms are often not as explicit as they are for benefits. Harm assessments are also more complicated because of the need to incorporate lower-level evidence from heterogeneous data sources as well as the fact that studies on harms may not be as reliable, valid, or robust as the studies on benefits. These complicating issues create additional uncertainty in assessing the balance of benefits and harms.

No formal approaches exist that provide guidance on how to grade the strength (or quality) of the evidence on the balance, or comparison, of the benefits and harms of interventions. Thus it is difficult to incorporate the various grades of the strength of evidence on benefits and harms into a summary assessment of the balance of benefits and harms. Decisionmakers are likely to find it difficult to balance multiple outcomes reported on various scales (relative or absolute) with varying strength of evidence ratings. Although the Grading of Recommendations Assessment Development and Evaluation (GRADE) approach rates the overall quality of evidence by considering the lowest quality of evidence among critical outcomes,26 that approach may not satisfy all decisionmakers.

## Challenges With Regard to Available Data

Most systematic reviews are based on available summary (i.e., aggregate) data.4,5 Thus, reviews usually only have access to marginal distributions of benefits and harms (i.e., separate results for each benefit and harm outcome) without information on the joint distribution of the outcomes (i.e., describing the correlation between benefit and harm outcomes). The joint distribution of the effects of treatment on the benefit and harm outcomes is seldom reported in studies. The studies only report separately on uncertainty, standard errors, and confidence intervals for each benefit and harm outcome. Without the joint distribution of all the effects, systematic reviewers have to assume independence of the benefits and harms, which may not yield a valid estimate of the uncertainty of the benefit and harm comparison metric. The joint distribution can be obtained via bootstrap methodology if individual-level data are available from the studies. However, this is not possible in meta-analysis of summary data. Given the limitations of the data, systematic reviewers are challenged to report an estimate of uncertainty (e.g., 95% confidence interval) around the benefit and harm comparison estimate if and when they decide such a benefit and harm comparison estimate is useful for decisionmakers.

In rare cases, individual patient data are available to systematic reviewers.3 Such data could include individual patient data from a subset of all studies, sufficient patient data from all studies, only marginally available patient data, or any combination thereof. The availability of individual participant data still requires careful consideration of salient analytical principles (such as whether all studies used an intention to treat analysis, or whether all studies had a sufficient duration of followup). For example, a recent individual patient data systematic review of inhaled budesonide among participants with chronic obstructive pulmonary disease reported no statistically significant increased risk of pneumonia with inhaled budesonide, but censored the analysis at 1 year of followup, despite having access to long-term data.27 Followup analysis of the same dataset yielded effect estimates that could not rule out a clinically significant excess of pneumonia in long-term followup. In this example, it is unclear whether the summary data of the entire body of evidence is more reliable than individual patient data from a subset of the evidence.

## Challenges With Regard to Scale of Treatment Effect

The analysis of benefits and harms in systematic reviews is challenged by the differences between the absolute or relative scales used for the analysis. The appropriate scale of analysis depends on assumptions about the causal effect. If the treatment is thought to have a multiplicative effect, then studies should use a relative risk scale to estimate the effect. If the treatment is thought to have an additive effect, then studies should use an absolute risk scale.28 However, in many cases it is unclear which scale of analysis is most appropriate. Benefits could be gauged on an absolute, continuous, or relative scale. The relative scale is used most often for reporting treatment effects.29 However, most quantitative approaches for assessing the balance of benefits and harms model data on an absolute scale, most likely because of the greater relevance of the absolute scale for clinical decisionmaking.13,29 In a meta-analysis of harms, which are usually relatively rare events, reviewers may choose to model data on an odds or relative scale because of their strong statistical properties.

## Challenges With Regard to Preferences

Systematic reviewers synthesize evidence on multiple benefits and harms to serve the needs of a variety of decisionmakers, such as guideline developers, payers, regulatory agencies, and ultimately patients and clinicians. Decisionmakers may have varying views about the relative desirability of different outcomes (i.e., preferences). For example, guidelines based on a systematic review of benefits and harms of strategies to prevent venous thromboembolism considered prevention of pulmonary embolism as a clinically important outcome, but prevention of deep vein thrombosis was not considered clinically important. 30 This was in contrast to other guidelines that considered both as clinically important outcomes.31 The GRADE working group also provides some guidance on the importance of considering health state preferences when making a treatment recommendation.26

Systematic reviewers may elicit preferences about the relative importance of the different outcomes during various stages of the process by obtaining input from a variety of decisionmakers or stakeholders. However, reviewers are challenged by how to make these preferences explicit. Although a systematic review that includes a key question on preferences related to outcomes and interventions (as opposed to the effectiveness of interventions) would be useful, such reviews are uncommon.

One problem is that systematic reviewers may find it difficult to incorporate values and preferences in benefit harm assessments without making treatment recommendations. Often, systematic reviewers are expected to review the evidence objectively without making specific treatment recommendations, leaving such decisions for policymakers that will have other contextual information (such as the availability of alternatives and the specific decisionmaking context). While including values and preferences regarding outcomes in a systematic review gets reviewers one step closer to making a treatment recommendation, it is still different from making treatment recommendations. Systematic reviewers should be aware of the narrow difference between drawing conclusions from a benefit harm assessment and making a treatment recommendation.