# Acknowledgments

The team would like to thank Daniela Puhan-Vollenweider, M.D., Manisha Reuben, and Renee Wilson for their assistance with the formatting of this report and Eric Vohr and Faye Rivkin for their editing and Dr. Parivash Nourjah for her valuable insight throughout the project. We also thank Dr. Kevin Frick for his valuable comments on a draft of the report.

Thank you to the following Technical Expert Panel members for their time and expert guidance:

Elie Akl, M.D.

University of New York

Buffalo, NY

Marguerite A. Koster, M.A., M.F.T.,

Kaiser Permanente, Southern California

Robert L. Kane, M.D.

University of Minnesota

Minneapolis, MN

Thomas A. Trikalinos, M.D., Ph.D.

Tufts Medical Center

Boston, MA

Wiley Chan, M.D.

Northwest Permanente

Thank you to the following Peer Reviewers for their time and expert guidance:

Jonathan Treadwell, Ph.D.

Evidence-based Practice Center, ECRI Institute,

Plymouth Meeting, PA

Robert L. Kane, M.D.

University of Minnesota

Minneapolis, MN

Joshua Cohen, Ph.D.

Tufts University

Boston, MA

Melissa McPheeters, Ph.D., M.P.H.

Vanderbilt University

Nashville, TN

Francois Sainfort, Ph.D.

University of Minnesota

Minneapolis, MN