# Acronyms/Abbreviations

A: Absolute
ARR: Absolute risk reduction
AHRQ: Agency for Healthcare Research and Quality
AHP: Analytic hierarchy process
B&H: Benefit harm
BLRA: Benefit-less-risk analysis
D: Difference
DD: Data driven
EBM: Evidence-based medicine
EPC: Evidence-based Practice Centers
GRADE: Grading of Recommendations, Assessment, Development and Evaluation
INHB: Incremental net health benefit
JAMA: Journal of the American Medical Association
M: Multiple
MAR: Maximum acceptable risk
MCDA: Multicriteria decision analysis
MCE: Minimum clinical efficacy
MERT: Minimum target event risk for treatment
NA: Not applicable
NCB: Net clinical benefit
NCI: National Cancer Institute
NNH: Number needed to harm
NNT: Number needed to treat
NNT/NNH: Ratio of number needed to treat over number needed to harm
NNTt: Threshold number needed to treat
O: Other
OR: Odds ratio
P: Possible
PICOTS: Population, Intervention, Comparator(s) Outcome(s), Timeframe, and Setting
PSM: Probabilistic simulation method
Q-Twist: (Quality-adjusted) time without symptoms and toxicity
QALYs: Quality-adjusted life-years
QFRBA: Quantitative framework for risk and benefit assessment
RBP: Risk-benefit plane
RBC: Risk-benefit contour
RCTs: Randomized controlled trials
RR: Relative Risk
RV-NNT: Relative value adjusted number needed to treat
S: Simulation
SPM: Stated preference method
TURBO: transparent uniform risk benefit overview
Q-TWiST: Time without symptoms and toxicity