# Summary and Implications

EPCs are conducting a growing number of reviews focused on behavior change literature. Behavior change interventions are used across a variety of health-related conditions, often in heterogeneous populations. Multiple outcomes may be studied, with outcomes individualized to the patient, and important outcomes may compete (for example, trading pain reduction for function). Interventionists often follow an approach that is theoretically and philosophically based, but modify the intervention to accommodate the needs and the interests of the individual, thus the interventions may be adapted to individuals within the studies. In addition, behavior change interventions are also intended to effect changes in how health care is provided to improve patient outcomes. These interventions are sometimes targeted to providers at the individual level, but may also involve system-level changes that aim to engineer systems that nudge or support individual behavioral changes. The nature of behavior change interventions make aggregation, synthesis, and communicating important findings of systematic reviews challenging.

Issues that create challenges in synthesizing behavior change literature arise in all main components of reviews, including setting the scope and key questions, study selection, data extraction, risk of bias, strength of evidence and presentation of results and conclusions. These issues are related in part to an overlapping but different set of study designs for which established guidance and methods are at times a poor fit (e.g. NRS), and for some even non-existent (e.g. SSED). There may be few RCTs or prospective studies available to review, and studies that are conducted may be small. Common study designs, analytic approaches, and the language used to describe behavior change intervention studies may be specific to the particular field and not clearly described in existing EPC methods.

In addition, many behavior change interventions are targeted to symptoms, rather than clinical conditions, and may be used and studied across a range of diagnosable conditions. Likewise, a particular symptom may be targeted by multiple behavior change interventions. The decision to focus on a symptom or an intervention and the range of conditions involved increases the complexity of the context and has implications for how to involve an appropriate range of stakeholders in the systematic review process. The prevalence of the use of multiple outcomes, which must be standardized for interpretation, adds to the difficulties. More fundamentally, though, the challenges arise from synthesizing bodies of literature focused not on obtaining average effects across generalizable populations, but on identifying and describing heterogeneity in treatment effects and populations.

Ultimately, the issue of whether useful information can be identified rests on strength of evidence. Under the traditional strength of evidence paradigms based on Bradford Hill guidelines, causal strength of evidence is determined by two factors – one is the confidence in the estimate of effect and the second is on the likelihood that additional research will change the findings. Low strength of evidence reflects limited confidence that the estimate of effect lies close to the true effect and that additional evidence is needed before concluding either that the findings are stable. In most cases, these two factors are in alignment. However, in the behavior health field, the study designs may limit the ability of the reviewer to conclude causality using only strong Bradford Hill guidelines, and future research is unlikely to provide any greater confidence, making it a challenge for decision-makers who must make decisions under such great uncertainty.

In addition, the question posed by a systematic review may be at odds with the focus of the studies themselves. For example, while policy makers may want to know about the overall comparative effectiveness of two interventions, the individual studies available to answer that question are instead often designed to focus on explicating the context in which the intervention is most effective. Forcing these studies into a synthesis approach that seeks an overarching effect in generalizable populations may miss important contextual questions that are considered important in the field. A focus on individualized outcomes is contrary to the usual conclusions of RCTs in which inferences are made at a generalizable, group or average level. Some of the literature our team identified published by other investigators and review groups suggested that in evidence-based practice the usual study design hierarchy may be inappropriate for studying the effectiveness of some behavior change interventions and is, in fact, “upside down.”12 In this view, the assumption that a sample does or should reflect a broad population with a defining clinical condition may be inappropriate and non-RCTs are preferred. Any differences observed in treatment effect are as likely to be about heterogeneity in the population as about treatment effects overall, especially in smaller studies, which are common in intensive, behavior change interventions. By the same token, a lack of observed effect may be due to heterogeneity masking a true effect in specific subgroups when an average effect is calculated. This philosophy is at odds with a system of risk of bias assessment and strength of evidence that prioritizes RCTs.15,25

Given these limitations and uncertainty, the question remains as to whether systematic reviews can synthesize evidence in a way that is more helpful to decision-makers. Such an approach might place greater emphasis on research that provides contextual information, and may require use of a larger variety of study designs, and a different approach for assessing SOE.26

While the current EPC guidance is intended to be applicable to all types of interventions, it does not specifically address differences in reviewing behavior change literature and does not provide advice on a number of issues, including an agreed upon approach to determine when populations and outcomes are similar enough to combine quantitatively, what additional measures of quality/risk of bias may be particularly important (e.g. fidelity), whether SOE grading can accommodate the need to distinguish between lower levels of evidence to help decision-makers. In the absence of guidance, methodological work in these specific areas may provide investigators more specific and relevant considerations for a more consistent approach for the program.

## Future Directions

The Workgroup for Intervention Development and Evaluation Research (WIDER) issued recommendations to improve the reporting of behavior change interventions, specifically calling on studies to provide a detailed description of interventions in published papers, clarify the assumed change process and design principles, provide access to intervention manuals/protocols, and provide a detailed description of active control conditions.27,28 These recommendations, if widely adopted, will yield substantially greater amounts of relevant information and will help systematic reviews answer the question of context-specific effectiveness, perhaps with existing quantitative tools. The uptake of these recommendations is yet untested. In the meantime, end-users of systematic reviews seek actionable information now on behavior change interventions.

Our workgroup identified three main opportunities for additional methods work. First, investigators can explore opportunities to shape reviews to incorporate and focus on context and “which interventions work best under which circumstances for which individuals or target groups.” Second, investigators can pilot methods and approaches in EPC program systematic reviews. Finally, the program is preparing to launch methods work in complex interventions, which is potentially applicable to behavior change interventions. This is an opportunity to leverage this work, and ensure applicability to a range of complex interventions, including behavior change interventions. As patient-centered outcomes research becomes more dominant in the field, the idea of synthesizing literature that focuses on describing heterogeneity more than reaching an overall estimate of effect is appealing but brings with it the challenges noted in this white paper. A decision to move in that direction requires examination of the methodologic issues raised here.

Key Observations

- Challenges of reviewing behavior change literature exist at each step of EPC systematic reviews.
- Challenges are particularly acute when fields are focused on identifying and describing heterogeneity in populations and treatment effects rather than identifying generalizable effects.
- A larger discussion is needed about how EPC program methods can meet the evidentiary needs and questions of decisionmakers, consistent with the Program's aim to provide accurate, independent, and scientifically rigorous information.
- Any methods approaches moving forward should address the specific needs of decision makers for using reviews of behavior change literature.