# Results

## Overview

We sought to identify key challenges to conducting reviews of behavioral interventions under the EPC Program, and to assess whether the sources of guidance typically accessed by EPC investigators hold recommendations to address these challenges. We conducted a literature search as described above, and consulted with key informants. In the literature search, we identified 243 unique references. Of these, we excluded 142 from further analysis because they did not address behavior change intervention research or methodologic issues related to behavioral-based interventions. From the set of 88 relevant papers, we categorized 27 as handbook or guidance; the remaining documents were categorized as research (27) or review articles (34). We selected the subset of these that would most likely inform the practice of EPCs for analysis below in the text, but provide an overview of the totality of what is available in the Appendix.

Documents ranged from publication guides, such as the extension of the CONSORT guidelines, to methods used by professional societies for their reviews and guidelines,5 to examples of detailed methods sections used at organizations that review behavior change interventions.6

Relevant guidance exists in the Cochrane Handbook, the USPSTF Methods Guidance, and in the NICE Guidance, although none of it claims to speak directly to the issues of behavior change interventions as distinct from other interventions. Of note, the Cochrane Handbook, particularly recognizes the challenges in conducting reviews that are almost exclusively or exclusively composed of non-RCTs, noting that these are “much more difficult than carrying out a systematic review of randomized trials.”7 The Cochrane Handbook sections on Special Topics is of particular use to the reviewer of behavior change interventions, as it includes guidance on the use of non-randomized trials, patient-reported outcomes, qualitative research, and public health and health promotion.

The USPSTF provides perhaps the most direct discussion of methods in their document on how to assess behavioral counseling research. They identify several key challenges to applying USPSTF systematic review methods, which overlap somewhat with the challenges our team identified. These include:

- Study populations that may be inadequately characterized to assess risk or that are extremely heterogeneous
- Need to assess feasibility issues, including ease of enrollment
- Outcomes and assessment issues, including the challenge of identifying adverse effects of behavioral interventions, and the use of multiple outcome measures to assess a common construct

Although the guidance recognizes these challenges, no solutions are provided for systematic reviewers. Instead, the recommendations sections focuses primarily on making recommendations to behavioral researchers in terms of how to conduct and report their research to make it more amenable to reviews.

## Specific Methodologic Challenges Faced by Investigators Conducting EPC Reviews of Behavior Change Interventions and Available Guidance

Below, we describe methodologic challenges as they pertain to study selection, data extraction, risk of bias assessment, strength of evidence and presentation, including applicability. These results reflect the experience of our workgroup, information from the literature and the thoughts of our key informants.

### Scope and Key Questions

#### Challenges

As described above, the most relevant questions for stakeholders in reviews of behavior change interventions are often less focused on what interventions work at an overall population level, but rather which interventions work best under which circumstances for which individuals or target groups. Theoretical models often have been developed to make the case for an intervention approach and the intervention may be available, but may have suboptimal outcomes unless appropriately targeted, or appropriately modified for fit to an individual who is undertaking the behavior change. Thus, the key questions might need to be disproportionately focused on subgroup analyses in some reviews in the behavioral literature.

In the same way, many behavior change interventions are multi-component and complex, and it would be reasonable to conduct reviews either of the complex intervention's effectiveness overall, or to try and tease apart the degree to which individual components drive positive outcomes. This determination drives the choice of key questions and ultimately the scope of the review.

#### Available Guidance

The USPSTF procedure manual describes guidance for the inclusion of contextual questions within the scope of a review. These address important issues that require a valid assessment but not necessarily a systematic review. This information though is not reported as systematic results, but provide context and are described in the background and discussion and may be helpful in providing additional information on the circumstances in which certain interventions may be most effective.

### Study Selection

#### Challenges

Study selection criteria typically are based on a predefined set of PICOTS, including for example pre-specifying a particular clinical population of interest. The full population serving as a target for a behavioral intervention may be defined more by characteristics and symptoms that cross clinical populations than by individual disease entities or syndromes, making searches broad and often unwieldy. Furthermore, the study design specification is often a challenge in reviews of behavior change interventions for the simple reason that there may be few RCTs or even comparative studies at all, with a frequent preponderance of single-subject design studies. The decision of whether to include and how to assess single-subject design research is complicated by a lack of guidance on how to do so. Because single-subject designs can take many forms, and are commonly misunderstood in medical research, we described single-subject experimental designs (SSED) in some detail below. Finally, PICOTs for health system level behavior change interventions may suffer from “square peg in a round hole” syndrome, since the PICOT components alone may not capture the many pathways and processes associated with behavior change. Issues related to PICOT definitions may be better addressed on a case-by-case basis, but the EPC program can consider if broad brush stoke guidance, tips, or best practices would be useful.

##### Uncontrolled Studies

Observational studies without a control group are often included in EPC reviews of medical interventions in order to assess rare adverse events. RCTs are often too small to detect very rare events, and subjects who are more susceptible to adverse events due to age or pre-existing medical conditions are usually excluded from RCTs. However, including uncontrolled studies in systematic reviews to estimate efficacy is controversial. In behavioral research fields, RCTs may be difficult to implement for several reasons. Consumer pressure for access to a treatment may discourage the use of a control group. For example, it is most effective to intervene with children with ASD as soon as diagnosed;8 many parents would not tolerate their child being assigned to a wait list or no treatment.

##### Conference Abstracts

These summarize presentations and posters presented at scientific conferences. Such presentations do not undergo the rigorous peer review required by academic and professional research journals, and often do not include important information needed for EPC reviewers to assess the quality, applicability, and generalizability of the study. However, in fast-evolving fields, they may be the only results available on a specific new intervention or special population.

##### Inclusion of Single-Subject Experimental Design Studies

Single-subject experimental designs (SSED) have been used for the past 25 years to study behavior change interventions targeting children with various psychological, psychiatric, and physical conditions.9 Single-subject designs have recently been introduced for medical research; AHRQ published a user's guide for the biomedical field in early 2014.^10^ In clinical medicine, so-called N-of-1 RCTs are multiple crossover trials, usually blinded and randomized, conducted in a single patient. More diverse single subject methods are used in the behavioral field, including reversal designs, multiple baseline designs, and designs with alternating treatments.11 Importantly, SSED studies in the behavioral field usually involve more than one individual.12 The intervention is applied to several subjects (usually fewer than 10) utilizing the same protocol and manual to maintain fidelity. In that way, researchers may isolate patient characteristics associated with improvement on an outcome.

Although not appropriate to determine overall effectiveness at the population level of an intervention, SSED have numerous important strengths. They may be conducted when an RCT is unfeasible because it is unethical to withhold treatment from a group. Also, they may be less expensive to conduct than RCTs and thus used to conduct important research when resources are lacking. Others use SSED based on the philosophical position that the best control for an individual patient is that same patient. In an era where patient-centered research is paramount, their focus on the effect of patient characteristics and specific intervention components may add depth and breadth to AHRQ systematic reviews, which often include Key Questions on special populations, timing, dosage, and program characteristics. Still, if SSED studies are to be considered for future inclusion in AHRQ systematic reviews, several important issues must be addressed. One KI noted a current project to develop Bayesian methods to estimate whether N-of-1 studies approximate results from RCTs.

Two KIs had included single subject research in their SRs, with a particular focus on capturing details of contexts under which specific interventions could be effective; all KIs had included other non-RCT designs. One KI's SR on alcohol policy even included an ethnographic study. One informant used separate teams in parallel to review the RCTs and the non-RCTs and abstract data simultaneously. This is done to avoid any bias that might come from knowing the results of one set of studies earlier.

##### Available Guidance

SSED typically have been excluded from EPC systematic reviews due to issues of statistical power and generalizability to a wider population. In fact, a 2010 AHRQ-funded project testing an instrument to classify study designs did not include single subject studies.13 The section on non-randomized studies in the Cochrane Handbook includes guiding questions to help investigators classify studies into different designs, but is limited to the “classic” designs in biomedical literature, excluding, for example, stepped-wedge, time series or single-subject experimental design. There is no information available on how to include single-subject experimental design studies, including assessing risk of bias and incorporating into an overall synthesis. Similarly, the EPC methods guide on risk of bias assessment includes a taxonomy of study types, but does not include single-subject experimental design.

One KI reported that the next version of the Cochrane handbook will include a chapter on qualitative research, although it was unclear if, when, and under what circumstances this would be done.

The EPC Program described a “best evidence” approach for study selection for a review.14 This entails weighing the trade-offs in risk of bias, applicability, replication, conclusiveness, and overall strength of evidence. While potentially applicable to behavior change intervention reviews, offers a general approach without more specific considerations for study types that may be considered higher risk of bias.

### Data Extraction

#### Challenges

Reviews of behavior change interventions often face a greater data extraction burden than reviews of drug interventions. At a very practical level this occurs, for example, when a drug can be described by a limited set of variables (e.g. name/chemical composition, dosage, frequency of administration) while a behavior change intervention may include many more components. This is a particular challenge when, as previously described, individual interventions are further tailored to the individual and therefore may have multiple forms or iterations. Unlike drug studies (but often similar to surgical or medical device interventions), the qualifications and skill level of the intervention provider(s) may also be important and should be captured in the data extraction. A study's attention to measuring fidelity to the intervention protocol should also be extracted including the specifics of how fidelity was assessed. Because of the additional information required to assess even simple single component behavior change interventions, full journal articles reporting study design and results are generally required even to assess inclusion, eliminating the benefit of initially reviewing abstracts.

Furthermore, the number of outcomes of interest is often substantially higher in behavior change studies, including individual components of behavior change measures in addition to overall assessments. Target outcomes are frequently individually established. Reviewers report little success in limiting the number of outcomes of interest with the help of content experts. This is very likely a reflection of a point raised by KIs that there is frequently little consensus among experts as to which scales or measures are most appropriately used in any given behavior change field to assess important outcomes. Whereas in many medical interventions outcomes such as mortality or specific morbidities are objectively determined and dichotomous, outcomes of interest in behavioral research are often assessed by patient self-report questionnaires or behavioral observations, with continuous outcomes. The degree to which these outcomes are validated varies substantially.

In childhood research, for example, there are many validated instruments used to measure the same construct such as social skills or adaptive behavior. KI who raised the issue agreed that translating into an effect size for the purpose of meta-analysis was considered acceptable in the educational and psychology fields, provided that the results were translated into meaningful information for the practitioner.

Thus the data extraction process, particularly around description of the intervention and the outcomes, is frequently substantially greater in behavior change reviews than in biomedical reviews. Potentially greater time and effort may be needed to identify and specify interventions and their components can have significant impacts on timeliness. However, scaling down the scope of a review in response may affect the relevance and usefulness of a systematic review.

##### Available Guidance

The EPC program is currently working to establish minimum reporting elements to describe complex interventions, and these may be used to guide date extraction processes. The Cochrane Collaboration has also been attending to this issue. However, since behavior change interventions can occur at any one of several levels of a health system, without actual published material it is unclear whether such guidance will be sufficient to address SRs evaluating patient behavior change interventions.

The Cochrane Handbook and EPC Program methods guidance15 also addresses patient-reported outcomes, and recommends specific considerations when assessing outcome measures for a review. Both note that systematic reviewers need to be able to assess the reliability and validity of outcome assessment tools to assess the risk of biased results. This implies a basic understanding of questionnaire development and validity literature can provide the background needed to assess whether or not an outcome assessment tool is reliable and has been validated. However the guidance does not specify minimum expectations for a valid and validated measure for inclusion in reports. Guidance does not also specify the extent to which reviewers should confirm the validity of outcomes measures and does not require expertise in measure development and validity.

### Risk of Bias Assessments

#### Challenges

Investigators on the team and KIs report an absence of established tools appropriate for assessing risk of bias in behavior change interventions. Underlying this lack of specific tools is disagreement in terms of what constitutes high quality behavior change research overall, including lack of consensus on which study designs are most appropriate (e.g. RCTs versus observational). As a result, there is some uncertainty as to whether the study design and rigor hierarchy accepted for biomedical research should be adopted across behavior research as well or whether a different model is best adopted. This includes disagreement about whether blinding is an essential element for risk of bias assessments in the behavior change literature and whether a behavior change study can have low risk of bias in the absence of blinding. This idea mixes concepts of study rigor with feasibility, reflecting the perceived difficulty of implementing good blinding procedures in behavior change studies.

#### Lack of Blinding

Bias can arise from lack of participant and personnel blinding to assignment and from lack of blinding of outcome assessors. For behavior change interventions, it may be difficult, and sometimes impossible, to blind participants and personnel because they often involve extensive patient and provider interaction and awareness of treatment components. Nonetheless, some outcomes such as objective cognitive assessments can be evaluated by blinded outcome assessors. For other outcomes such as self-reported symptoms, the risk of bias is compounded by the lack of patient or personnel blinding of assignment. The inherent difficulties of achieving patient or personnel blinding in behavioral interventions mean that many behavioral interventions may be rated as having a higher overall risk of bias than interventions that can more easily blind patients or personnel.

If blinding, regardless of feasibility or appropriateness, is an important measure of rigor, then by definition, many behavior change interventions can never be assessed with the highest rigor. Some SR approaches, such as that espoused by the US Preventive Services Task Force, exclude studies with a high risk of bias. In such cases, behavioral interventions may be disproportionately excluded from the body of evidence, resulting in instances where the review is unable to make a conclusion because of the lack of high-quality evidence. One must ask the question of “why bother” with a risk of bias assessment in which the assessment is dictated by the field, not by the study conduct. Certainly, some behavior change studies have used unique and creative methods of maintaining patient and provider blinding,16 these methods are often difficult to implement and are not commonly used. Thus, researchers are currently struggling with the question of whether key sources of bias in behavior change interventions center around blinding as often is the case in medical interventions, or whether other factors should carry more weight in assessing risk of bias. We did not find consensus on this issue.

##### Fidelity

Although the risk of performance bias, due to lack of fidelity, is not unique to behavioral interventions, behavior change interventions may include more intervention elements or intervention elements with a high degree of potential customization. In such interventions, the risk of performance bias may be elevated when fidelity to core and planned interventions is not monitored during the course of the intervention.

##### Rating Study Quality of SSED

Factors that increase internal validity of SSED include dual assessment of observed outcomes, inter-observer reliability, and collection of data at multiple time points in the absence or presence of the behavior change intervention. However, no quality rating instrument has been widely accepted. In 2008, Logan and colleagues published a 14-item instrument developed to rate the quality of an SSED study as strong, moderate, or weak.17 This instrument assesses aspects such as sufficient description for replicability, blinding of outcome assessment, and measure variability during the baseline period. The authors suggest that a high quality SSED will include at least three patients and five data points in each phase. Other important issues such as random allocation, loss to follow-up, and data missing at different time points are not addressed by the instrument. Logan et al. also proposed a five-level hierarchy of evidence for SSEDs, with N-of-1 RCTs at the top. In 2013, Tate and colleagues published the RoBiNT Scale, another instrument for rating quality.18 It includes 15 items in all, split in two subscales for internal and external validity, respectively. The first scale includes items on randomization, sampling, and blinding and the second scale focuses on aspects of thorough reporting and data analysis. Both the Logan et al. instrument and RoBiNT have displayed good construct validity and inter-rater reliability. Notably, both instruments go beyond traditional risk of bias (internal validity) concerns of instruments such as the Cochrane RoB tool to evaluate replicability17 external validity.19 SRs that use tool such as the Cochrane RoB instrument for trials and RoBiNT for SSED for the same evidence base will need to address the lack of concordance in underlying risk of bias criteria.

#### Available Guidance

None of the typically used sources of guidance provide risk of bias tools for use in the full range of study designs seen in the behavioral literature, although tools designed for cohort studies can often be adapted for this use. EPCs have typically developed their own approaches and use of the newest guidance on risk of bias does provide a bank of questions20 that can be used for this purpose. Nonetheless, a determination of the applicability of approaches for assessing other study designs such as the SSED is currently unavailable.

### Synthesis

#### Challenges

Although a detailed review of all the issues related to synthesis, including quantitative analysis, in reviews of behavior change interventions is beyond the scope of the current manuscript, one increasingly important issue involves the use of patient-reported outcomes. Behavior change interventions often involved the use of patient-reported outcomes. Patient-reported outcomes for behavior change interventions generally involve continuous measures and, for many outcomes, many different continuous measures exist purporting to assess the same (or at least similar) underlying constructs. Existing guidance recommends against combining measures of different underlying constructs, but does not make specific recommendations about how to make these determinations. Additionally, existing guidance recommends using the standardized mean difference (SMD) to combine different continuous measures of the same construct in meta-analysis, but also states that the use of SMDs may be problematic for this purpose in certain situations.7,21

##### Complex or Multi-Component Interventions

In order to determine which intervention components are driving effectiveness and identify standardized effect measures, statistical techniques such as SEM or other multivariate and modeling analysis methods are often employed. Additionally, these types of analyses of multiple treatment components require statistical adjustment for multiple comparisons in order to ensure that statistical assumptions are met. While some of these analytic approaches to multi-component interventions are described in recent AHRQ publications, existing guidance does not specifically address analytical approaches applied to behavior change interventions,2 leaving reviewers with little guidance on what data points to extract.

#### Available Guidance

The Cochrane Handbook examines the issue of multiple patient-reported outcome measures used for a particular construct that must be somehow synthesized. The guide states, “Investigators must … fall back on intuitive decisions about the extent to which different instruments are measuring the same underlying construct. For example, the authors of meta-analysis of psychosocial interventions in the treatment of pre-menstrual syndrome faced a profusion of outcome measures, with 25 patient-reported outcomes reported in their nine eligible studies. They dealt with this problem by having two investigators independently examine each instrument – including all domains – and group them into six discrete conceptual categories; discrepancies were resolved by discussion to achieve consensus. The pooled analysis of each category included between two and six studies.”

A number of organizations and texts provide support for and guidance in quantitative synthesis of behavioral interventions, particularly traditional meta-analysis. The Campbell Collaboration, for example, emphasizes meta-analysis with a focus on calculating standardized effect sizes, given the heterogeneity of outcome measures commonly assessed in behavioral studies. Decisions about when and under what circumstances to combine studies quantitatively, particularly in the presence of heterogeneous outcome measures or populations may warrant some discussion at the program. The question may not just be how much heterogeneity is acceptable or not acceptable, but also how to identify the range of outcome responses across the populations so that effective responses are not washed out of the information.

Cochrane Chapter 9.2.3 on standardized mean differences provides guidance on the calculation of standardized mean differences, but concludes that methods of interpretation of SMDs remain unsatisfactory, although as we note, these approaches are often the best available for behavior change intervention reviews. They do specify that methods for synthesizing qualitative methods are evolving but not recommend at this time (e.g., meta-ethnography).

The EPC Program has embarked on methods work in integrating randomized and non-randomized bodies of evidence in a review. While it may be helpful to the program, it may not apply as directly to behavior change interventions.

### Strength of Evidence

#### Challenges

Given the types and limitations of behavior change intervention research – including study designs for which the EPC program does not have a risk of bias tool consistently used across the program – incorporating behavior change studies into strength of evidence assessments is particularly challenging. Other challenges include the frequently substantial variation in the interventions across the studies, and the wide range and number of individual outcome measures used, which complicate decisions about when to lump or split studies for SOE assessments.

Other organizations have developed SOE-type systems specifically describing recommendations for incorporating SSED, but none of these organizations is one that EPCs would be likely to refer to for systematic review methodology (see below). Therefore, while these methods exist, they have not been vetted for use in EPC reports and would be unlikely to be adopted (and indeed have no been in relevant reports).

For example, Horner et al.22 suggested the following criteria be met for a behavior change intervention investigated by SSED to be considered “established,” which is their highest classification:

“[1] a minimum of five SSED studies on the treatment have been published in peer-reviewed journals that meet minimally acceptable methodological criteria and document experimental control; (2) the studies are conducted by at least three different investigators across three different locations; and (3) the studies include a total of at least 20 participants.”

The National Autism Center used very similar criteria in its recent National Standards Report (NSR).6 An intervention may be rated as “established” if there were at least “4 single subject experimental design (SSED) studies with a minimum of 12 total participants for which there are no conflicting results” or “6 SSEDs with a minimum of 18 total participants with no more than one study reporting conflicting results” as long as these studies scored three or higher on a five point quality measure developed by the NAC. NAC classified 11 behavior change interventions for autism as established. These conclusions are in marked contrast with the recent AHRQ funded systematic review on the same topic, which found insufficient evidence of efficacy for all behavior change interventions except one early intervention model, classified as low SOE. As this example demonstrates, varying standards can lead to conflicting results in different reviews of the same topic, leading to a potential lack of confidence in SR methods and results.

The American Psychological Association23 and the CDC provide guidance on incorporating the results of single subject research into SRs that included other study designs; however, there is no consensus in this area or validated method of rating Strength of Evidence (SOE) in such cases.

#### Available Guidance

Overall, guidance for questions that are associative rather than causal, and aimed at understanding context or context-specific effectiveness is not well developed. Strength of evidence techniques and guidance for questions answered by non-causal quantitative methods, or qualitative methods to gain insight into contextual issues are not articulated. Further, while not yet published, strength of evidence methodology for qualitative research, CerQUAL, was presented at a recent GRADE DECIDE conference in June 2014. The discussion for Question 2 of this paper also mentioned approaches and techniques for evaluating a body of evidence based on SSED.

The EPC Program recently published updated guidance for strength of evidence assessment, but does not describe particular considerations for different types of bodies of evidence, and how to translate strength of evidence grades for population-level research to individuals, local settings, systems, or healthcare providers.

None of the guidance documents examined included guidance about how best to evaluate or to include SSED in a strength of evidence assessment.

### Presentation of Results and Conclusions, Including Applicability

#### Challenges

Because behavior change interventions can involve complex patients, complex interventions, or both, presenting results and conclusions can be challenging. In quantitative synthesis, effect measures are commonly standardized and lack immediate clinical interpretability. In many cases, quantitative synthesis is not possible, and with significant variation in studies and outcomes, tables and descriptions become long and may seem to lack synthesis. Since results may be organized in several reasonable ways, guiding the reader by providing general text outlining the organization becomes more important.

##### Applicability and Generalization

Studies used in behavior change studies often rely on convenience samples and a small number of patients.12 Thus, the results are not generalizable to the entire population living with a particular condition and it may be reasonable to suggest that they may not be appropriate for obtaining overall estimates of effect. Applicability is difficult to assess. Indeed, the challenge is in defining what is a “representative population” for a particular behavior change intervention. SSEDs are a relatively extreme illustration of this problem. Some behavioral researchers suggest that SSED has so-called “logical generalizability” meaning that once SSED studies have been replicated many times, the results are applicable to patients with similar characteristics to those enrolled. This would, in turn, help describe the population the sample represents. This concept has not been validated empirically12 but in theory, the SSED literature could be compiled to address subpopulations of special interest in systematic reviews. Of course, subject selection and characteristics would need to be described with replicable precision in the SSED articles.

Generalizability for SSEDs may also be conceived of as across settings for one individual rather than across individuals and if this approach is used, it should be clearly specified in systematic reviews. One KI suggested that SSEDs are best used when the goal is to understand how a behavioral intervention works for one individual. For example, an SSED may vary the settings in which the intervention is used – the clinic, at home, at school, at a grocery store – for evidence of the learning process underway and that the behavior change intervention is generalizable to multiple settings.

SSEDs are an extreme form of the broader issue of whether generalizability as generally conceived is a logical aim for conditions or syndromes that are highly heterogeneous. Such heterogeneity is often due to the multiple pathways through which a condition or syndrome develops. Or the heterogeneity may be due to the complexity of the existing patient characteristics present at the time the intervention is fielded that create the patient conditions within which intervention interacts to effect change. The presentation of results that don't conform to the standard of identifying a main effect size that combines the effects in individual studies is challenging. Reviews of behavior changes interventions are likely to have greater emphasis on subsets than a main effect, multiplying the need for the number of individual results presented in the text and complicating the ability to present a straightforward message. Applicability by patient patterns is not as easily incorporated by guideline developers into broad guidelines, and may be more challenging for clinicians to use and apply. More particular findings, and the guidelines that would result, are more challenging to effectively communicate.

#### Available Guidance

The EPC methods guide indicates that applicability may depend on end-user needs, and the type of review question. Thus it recommends consultation with stakeholders to identify the most important factors that may affect applicability. The approach to assessing applicability in the EPC methods guide24 includes using elements of the PICOTS to assess and judge applicability of individual studies and the body of evidence. These elements can inform judgment about differences in treatment outcomes, related to effect modification, variance in absolute benefits and harms, and generalizability to everyday practice. Factors affecting applicability and differences between the review evidence and ideally applicable evidence should be described to assist decisionmakers.

The Cochrane Methods Guide7 also notes the importance of identifying effect modifiers, differences in baseline risk, and identifying important variation across populations. Guidance recommends identifying groups with varying risk in the summary of findings table, and when making an assessment of applicability consider whether why evidence should not be applied to a particular patient. Important areas of variation that may limit applicability include biologic variation, context and culture, adherence, and values and preferences.

This guidance provides a general and flexible approach. Investigators can include other elements relevant to complexity seen with behavioral interventions. Forthcoming guidance related to complex multicomponent interventions may inform these efforts.