# References

1 Glasziou P, Chalmers I, Altman DG, et al. Taking healthcare interventions from trial to practice. BMJ. 2010;341.
2 Guise J-M, Chang C, Viswanathan M, et al. Systematic Reviews of Complex Multicomponent Health Care Interventions. AHRQ Publication No. 14-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Connelly J. The Behavior Change Consortium studies: missed opportunities—individual focus with an inadequate engagement with personhood and socio-economic realities. Health Education Research. 2002;17(6):691-5. [pmid: 12507344].
4 Glasgow RE, Dzewaltowski DA, Estabrooks PA, et al. Response to Connelly. Response from the Behavior Change Consortium Representativeness and Translation Work Group: the issue is one of impact, not of world view or preferred approach. Health Education Research. 2002;17(6):696-9. [pmid: 12508811].
5 O'Donnell M, Darrah J, Adams R, et al. AACPDM methodology to develop systematic reviews of treatment interventions. American Academy for Cerebral Palsy and Developmental Medicine. 2004:1-30.
6 National Standards Report National Autism Center. Randolph, MA. National Autism Center. 2009. http://mn.gov/mnddc/asd-employment/pdf/09-NSR-NAC.pdf.
7 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions. Version 5.1. 0 [updated March 2011]. The Cochrane Collaboration. Cochrane Collaboration. March. 2011. http://handbook.cochrane.org/.
8 Taylor JL, Dove D, Veenstra-VanderWeele J, et al. Interventions for adolescents and young adults with autism spectrum disorders. AHRQ Publication No. 12-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
9 Maggin DM, Odom SL. Evaluating single-case research data for systematic review: A commentary for the special issue. J Sch Psychology. 2014;52(2):237-41.
10 Kravitz RL, Duan N, The DEcIDE Methods Center N-of-1 Guidance Panel. Design and Implementation of N-of-1 Trials: A User's Guide. AHRQ Publication No. 13(14)-EHC122-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Single-case experimental designs. Workshop on Innovative Study Designs and Methods for Developing, Testing and Implementing Behavioral Interventions to Improve Health. 2014. Bethesda, MD.
12 Schlosser RW. The role of single-subject experimental designs in evidence-based practice times. Focus. 2009;22:1-8.
13 Hartling L, Bond K, Harvey K, et al. Developing and testing a tool for the classification of study designs in systematic reviews of interventions and exposures. AHRQ Publication No. 11-EHC007-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2010. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
14 Treadwell JR, Singh S, Talati R, et al. A Framework for “Best Evidence” Approaches in Systematic Reviews. AHRQ Publication No. 11-EHC046-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Hatcher S, Sharon C, Parag V, et al. Problem-solving therapy for people who present to hospital with self-harm: Zelen randomised controlled trial. The British Journal of Psychiatry. 2011;199(4):310-6. [pmid: 21816868].
17 Logan LR, Hickman RR, Harris SR, et al. Single subject research design: recommendations for levels of evidence and quality rating. Developmental Medicine & Child Neurology. 2008;50(2):99-103. [pmid: 18201299].
18 Tate R, Perdices M, Rosenkoetter U, et al. Revision of a method quality rating scale for single-case experimental designs and n-of-1 trials: The 15-item Risk of Bias in N-of-1 Trials (RoBiNT) Scale. Neuropsychological rehabilitation. (ahead-of-print). 2013:1-20.
19 Tate RL, Perdices M, Rosenkoetter U, et al. Revision of a method quality rating scale for single-case experimental designs and n-of-1 trials: The 15-item Risk of Bias in N-of-1 Trials (RoBiNT) Scale. Neuropsychological Rehabilitation. 2013;23(5):619-38. [pmid: 24050810].
20 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epi. 2012;65(2):163-78.
21 Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
22 Horner RH, Carr EG, Halle J, et al. The use of single-subject research to identify evidence-based practice in special education. Exceptional Children. 2005;71(2):165-79.
23 Thygeson M, Peikes D, Zutshi A. Mixed Methods: Fuzzy Set Qualitative Comparative Analysis and Configurational Comparative Methods: Powerful Methods to Study and Refine Patient-Centered Medical Home Models. AHRQ Pub No: 13-0026-EF. Agency for Healthcare Research and Quality. February. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
24 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of clinical epidemiology. 2011;64(11):1198-207. [pmid: 21463926].
25 Berkman ND, Lohr KN, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the effective health care program of the Agency for Healthcare Research and Quality: an update. AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
26 Howick J, Glasziou P, Aronson JK. The evolution of evidence hierarchies: what can Bradford Hill's ‘guidelines for causation’contribute?. Journal of the Royal Society of Medicine. 2009;102(5):186-94. [pmid: 19417051].
27 Albrecht L, Archibald M, Arseneau D, et al. Development of a checklist to assess the quality of reporting of knowledge translation interventions using the Workgroup for Intervention Development and Evaluation Research (WIDER) recommendations. Implement Sci. 2013;8:52. [pmid: 23680355].
28 Michie S, Fixsen D, Grimshaw JM, et al. Specifying and reporting complex behaviour change interventions: the need for a scientific method. Implement Sci. 2009;4(40):1-6. [pmid: 19123945].