# Methods

## Overview

A workgroup of members from EPCs, the Scientific Resource Center (SRC), and AHRQ was convened to describe systematic review methods for behavior change interventions in the EPC and similar programs, and identify gaps in guidance. Workgroup members participated in bimonthly teleconference calls to discuss project direction, assign tasks, and review draft documents. Complementary methods including a literature scan and key informant interviews were undertaken to reach the objectives. A literature scan was conducted to identify current guidance and methods literature on the inclusion of behavior change literature in systematic reviews. Interviews were held with thought leaders in the field to identify current practices and opinions on using behavior change literature. Workgroup members summarized information from the literature and interviews.

## Literature Scan

To identify literature that addressed methods for including studies of behavior change interventions in systematic reviews, we searched multiple databases including MEDLINE via PubMed, PsycInfo, and ProQuest. We used a series of iterative strategies in each database including controlled vocabulary and key word terms such as research design, evidence-based medicine/methods, epidemiologic methods, and systematic review; and searches of journals that report methodologic studies (e.g., Journal of Clinical Epidemiology, Behavioral Research Methods) along with key words such as methodology or protocol following items related to particularly relevant studies identified in the searches. We searched gray literature to identify guidance from organizations completing systematic reviews of behavioral studies. Organizations include the Cochrane Collaboration, the Campbell Collaboration, US Preventive Services Task Force (USPSTF), Community Preventive Services Task Force, and the NICE. We also searched the EHC library of methods-related papers and guidance and the list of Effective Health Care (EHC) Program published reviews.

Investigators reviewed the retained materials for coverage of methodologic topics specific to the appraisal and synthesis of behavior change interventions. Data were extracted for each of the retained references to indicate methodologic topic coverage and record descriptions. We used a broad set of criteria to identify existing guidance and other relevant materials from the search results. We retained and categorized results as manuals, guidance, handbooks, or review methodology, with special attention to the materials authored or adopted by entities that assess behavior change interventions. We also retained supplemental publications that described the development or provided a detailed description of the guidance.

We conducted a preliminary scan of AHRQ EHC reviews to identify example reports that address studies of behavioral-based interventions (Appendix A). Two staff members reviewed the key questions, scope, and methods and results of each to identify relevant reviews. We recorded whether or not each review included behavior change interventions and if those assessments were described in the methods section.

## Review of AHRQ EHC Reviews

The workgroup identified exemplar AHRQ EHC reviews that described various approaches to challenges of behavior change intervention reviews. Approaches to addressing behavior change interventions in reviews were summarized and are available in Appendix B.

## Key Informant (KI) Interviews

We conducted open-ended interviews with six key informants for this project. Five were affiliated with universities in the United States or UK; one worked for the Centers for Disease Control and Prevention (CDC). One was chair of the methods group of the Campbell Collaboration at the time of the interview. All had several years of experience conducting systematic reviews of public health, behavior change, or educational interventions. Each KI completed an “EPC Conflict of Interest Disclosure Form” prior to being interviewed and no disclosed conflicts precluded participation of any of the invited organizations. A list of the key informants is provided in Appendix C. An interview guide was developed and used to prompt discussion during the interviews (Appendix D). The interview guide covered practices and challenges in conducting reviews of behavior change interventions including which study designs can be included, when to focus at the population versus the individual level, which questions should be answered by reviews of behavior change interventions, and whether or not behavioral interventions can be used to establish effects in systematic reviews. Investigators interviewed KIs about their experiences in producing reviews of behavior change interventions. All interviews were digitally recorded and transcribed and the transcripts were reviewed to identify and code key themes using NVivo software. The interviews focused on how and when these experts incorporated studies of behavior change interventions into systematic reviews. In addition, two KI interviews for another EPC Program Methods Workgroup on integrating bodies of evidence touched on relevant issues, so we included their feedback where appropriate.