# Background

## Objectives

This white paper is the result of a scoping exercise that describes the challenges faced by systematic reviewers in the Evidence-based Practice Center (EPC) Program when reviewing behavior change interventions, and considers whether current guidance is specific enough to address these challenges. This lays the groundwork for consideration of next steps in methods development.

## Rationale

For the purposes of this white paper, behavior change interventions are defined as interventions intended to change behavior at the individual level for the purposes of improving a health outcome. End-users of systematic reviews of behavior change interventions generally seek an improved understanding of which interventions work, for whom, and under what conditions.1 In other words, the most useful systematic reviews address both causality and context: they place equal emphasis on whether an intervention works for anyone and in whom and under what circumstances it has an effect. Even for interventions that rely on explicitly tested biological mechanisms and do not require individual behavior change other than adherence to medication plans, effectiveness can be altered by variations in the dose, duration, and timing of the intervention.1 Systematic reviews for biomedical interventions generally control for rather than explain these sources of variation.2 Behavior change interventions include much greater complexity and therefore have many more sources of variation than biomedical interventions. Thus, behavior change interventions raise particular challenges in terms of answering questions of context-specific effectiveness.

First, complexity is magnified significantly for behavior change interventions that rely on complex causal mechanisms requiring several intermediate changes before health outcomes improve. Second, actors at multiple levels (individuals, providers, systems, and policy) may all influence behavioral change: studies vary in the degree to which they account for the interplay among these actors and settings. Third, the longstanding debate on the relative weight and importance of these agents of change at different levels in influencing behavior change influences the types of designs and resultant information available to synthesize.3,4 Studies that focus on individual agency may use traditional experimental or quasi-experimental designs that are amenable to systematic reviews but produce relatively little information on the interplay between intervention and context. Studies that focus on context (often including qualitative components or qualitative design) may be limited in their ability to produce generalizable information. Fourth, studies do not always articulate or report on the components and characteristics of the intervention arm and any control arms, the theorized causal mechanism, and the fidelity of the intervention as implemented. Finally, the tools available to systematic reviewers (largely quantitative) to deal with heterogeneity are limited in their ability to explain context-specific effectiveness when primary studies do not articulate or report on mechanisms of change.

We further refine behavior change interventions for this paper to specifically include interventions intended to change patient behaviors. Thus, in addition to the complexity of interventions that often involve multiple components and may require change at the health services level, patient behavior change interventions can be seen as incorporating the patient as part of the intervention. In order to achieve the final health outcome targeted, such as reduction in mental health symptoms or avoiding diabetic complications, patients themselves must change the behaviors that contribute to worsening health states, or add behaviors that may improve health states, and sustain those changes over time. Behavior change for an individual is actually part of the intervention that leads to health outcomes and can be measured as “process” or intermediate outcomes (Figure 1). The mechanisms of change for individual behavior change, then, would include the psychological processes that interact within an individual to produce sustained behavior change. Accordingly, while a recent EPC methods paper published on systematic reviews of complex multi-component interventions2 and the on-going efforts to develop methods for complex interventions overlaps with and informs our discussions, our focus on patient behavior change interventions provides a unique contribution. However, a similar framework, and more familiar, could be constructed with an intervention box comprised of clinic-level behaviors (patient-centered medical home, for example), individual provider behaviors (behavior changes specific providers are required to adopt), and other contextual factors.

Figure 1 Behavior change for individuals

A flow chart. One box on the far left contains the text “Review population of interest”. An arrow from this box pointing right to a vertical series of four connected boxes. The top box contains the text “Intervention bundle”. Below this box are three boxes containing the text “Provider behavior: Therapy, Education, Feedback”, “Patient behavior: Mental, Physical”, and “Contextual or other system level support components” respectively. An arrow from this series of boxes points to the right to a single box containing the text “Short term: Intermediate behaviors, stteps, or outcomes”. A corresponding arrow points from this box to the left back to the series of four boxes. Another arrow points from the single box to a last box on the far right containing the text “Finhal health outcome such as improved symptoms, prevented health deterioration”.

Also concurrent with this project, a different workgroup is developing guidance for the potential contributions of non-randomized studies (NRS) to comparative effectiveness reviews, and how NRS should be treated in such reviews. Behavior change interventions are very often assessed with NRS designs. At the clinic level, NRS designs often include pre/post designs with or without comparators or interrupted time series. For patient behavior change interventions, the analogous study design is a single-subject research design (SSRD), although SSRDs can be either randomized or not randomized. This paper will explicitly examine implications of this study design for patient behavior changes.

This workgroup was convened to consider whether there are methodologic challenges that are unique to, or more salient to, reviews of behavior change, and if so, whether existing EPC guidance documents adequately provide guidance for conducting systematic reviews of behavior change interventions. Each of the workgroup members has worked on reviews previously in which experts in behavioral research have suggested through peer or public review that the EPC methods are necessarily too limited to appropriately gauge the effectiveness of the primary literature in their field. We sought to determine whether this was true and whether any aspects of guidance warranted expansion or clarification.