# Key Informant Interview Guide

## Introduction

The overall mission of the Agency for Healthcare Research and Quality's (AHRQ) Effective Health Care (EHC) Program is to provide evidence-based information to health care stakeholders that is relevant to their needs, timely, objective, scientifically rigorous in construct, and developed and presented with transparency. In the production of systematic reviews, we aim to answer questions about effectiveness of interventions and average population effects. We are aware that for certain conditions and behavioral interventions, these questions may miss important issues.

AHRQ engages stakeholders in all facets of their research enterprise, including the producing of systematic reviews, with the goals of ensuring that research findings reflect the needs of diverse users, are relevant to their unique challenges, and are applicable in real-world situations.

## Purpose of the discussion session

The goal of our project is to better understand the questions that should be asked about behavioral interventions. Additionally, we would like to understand methods used and challenges encountered in including behavioral literature in systematic reviews, including which study design types are included in reviews.

We are very interested in learning from your experience.

There are not right or wrong answers, so please feel free to share your thoughts openly.

We would welcome any materials that you would like to share with us either before or after the discussion session. Please send any materials to Johanna.anderson2@va.gov.

## Ground rules for discussion session

The discussions will be tape recorded, transcribed, and analyzed for overarching themes.

Although the report may list individuals who were interviewed, answers will not be identifiable to individuals or specific organizations.

You may refrain from answering any questions and are welcome to leave the discussion at any time.

## Interview Guide

1. How long have you been conducting systematic reviews which include behavioral interventions?
2. What type of behavioral interventions have you studied? For what conditions?
3. In systematic reviews, what are the right questions to ask for patients who receive behavioral interventions?
  a. What works?
  b. For whom and how?
  c. How separable or combinable are these questions for patients who receive behavioral interventions?
4. What research study designs flow from these questions in your evidence synthesis process?
5. At what point do we shift attention from the population to the individual? How do we present effectiveness as a distribution rather than a point estimate?
6. What kind of data could answer these questions and how might that data be analyzed or presented? (Example?)
7. What are the implications for assessing strength of evidence? How do you pull together qualities to understand how strong evidence is?
8. What are your thoughts on how to assess internal validity in these studies?
9. In our process, we separate applicability and internal validity. When do you feel it is okay to separate external from internal validity?
10. What is your viewpoint on using behavioral interventions to establish an effect in a systematic review?