# Key Informants

- Andrew Booth, Dip. Lib., M.Sc., MCLIP
  Co-Covenor
  International Cochrane Collaboration Qualitative
  Research Methods Group
  Sheffield, UK
- Robert Hahn, Ph.D., M.D.
  Senior Scientist
  U.S. Task Force on Community Preventive Services
  Atlanta, GA
- Mark Petticrew, Ph.D.
  Director
  Public Health Research Consortium
  London, UK
- Therese Pigott, Ph.D.
  Co-Chair and Editor
  Campbell Collaboration Methods Group
  Loyola University Chicago
  Chicago, IL
- Brian Reichow, Ph.D., BCBA-D
  Assistant Professor (Adjunct), Associate Research Scientist
  Child Study Center, Yale School of Medicine
  New Haven, CT
- Ken Reniscow, Ph.D.
  Chair
  Society of Behavioral Medicine, Evidence-based Behavioral Medicine (EBBM) Committee
  Ann Arbor, MI
- Christopher Schmid, Ph.D.
  Director, Professor
  Biostatistics, Brown University
  Center for Evidence Based Medicine
  Providence, RI