# Approaches to Addressing Behavior Change Interventions in EPC Reviews

EPC reports that included a behavior change intervention focused on a broad variety of topics. These included mental health (depression), behavioral condition, or a medical condition (such as asthma, nephrolithiasis, and weight gain prevention) or a nonclinical topic that included an intervention aimed at behavior change (such as consumer health informatics, public reporting, and provider adherence to asthma guidelines). From these reviews we provide examples of various approaches to challenges.

## Review Scope and Key Questions

Many reviews included additional questions to provide relevant information for stakeholder decisionmaking, in addition to questions related to effectiveness. These questions explored issues such as contextual factors;1-3 analysis of intervention features of more effective interventions;4-5 usability (public reporting);6 and implementation strategies.7 For example, a review on autism5 included a question on treatment modifiers in addition to a question on intervention effectiveness. Treatment modifiers included intervention features, context and patient characteristics. Investigators noted that few studies were designed or powered to identify modifiers of treatment effect. They described the three studies that were, and further described potential factors described in the other included studies that warranted further study.

In a review of autism in children,5 in addition to effectiveness questions, the authors assessed the evidence for the presumed mechanism of action, linking the intervention targeting the behavior (such as maladaptive behavior), functional outcome (psychosocial adaptation), and the long-term outcomes. In their analytic framework, they assumed that improvements in treatment outcomes would lead to improved functional outcomes, and then long-term clinical outcomes. They included questions about predictors of favorable treatment outcomes (shorter term intermediate behavioral outcomes), and whether favorable treatment outcome predicted favorable functional outcomes. These questions explored not only predictors of response, but potentially the assumed association between behavioral and functional outcomes.

## Study Selection

A design other than the RCT may have been chosen by a primary researcher because of feasibility, ethical issues, or cost. This poses difficulties for a review focused on establishing causality. Almost all reviews included key questions focused on global effectiveness, and a variety of study designs were included to answer this question, most commonly RCTs. Most often the rationale if given for inclusion of a greater variety of study designs was the relative lack of RCTs.8 How far investigators chose to go in the evidence hierarchy was a balance between the volume of literature and presumed risk of bias (and ability to establish causality) based on study design. For example in an autism report5 single-subject design studies were excluded. They noted that these studies could assess treatment response in short timeframes and under very tightly controlled circumstances, but could not provide information on longer term or functional outcomes, or external validity.

Investigators used a different body of studies depending on the type of questions in the review's scope. For example, in an evidence review on health information technology use,9 the authors acknowledged that RCTs were optimal for assessing outcomes, but other study designs were appropriate for other types of questions. Thus they included epidemiologic studies and qualitative research to inform questions about barriers, drivers, and usability. In a review of the PCMH, investigators included studies without a comparator when describing implementation strategies.3

## Meaningfully Categorizing and Describing Interventions

EPC reviews have categorized interventions, both with and without behavior change interventions, by programs;10 individual components11 or bundles of components2 using existing taxonomies. Choice of approach depended on the granularity of the review question and end-user need. For example in a review of screening for alcohol misuse,12 behavioral interventions were grouped as low and high intensity. This was done because the review was used to inform a recommendation on screening, rather than effectiveness of one behavioral counseling approach over another. Another review, on modification of cardiovascular risk factors in individuals with SMI, Gierisch et al.13 took a more general approach and analyzed all behavioral interventions together as a group, and compared them to usual care.

Grouping multi-component interventions was a challenge. In another review on medication adherence for hepatitis C treatment, interventions were grouped by intervention target-policy, regimen, patient, adverse event management, or provider.14 Investigators were unable to group at a more granular level for most categories, such as intervention bundle, component, or level of intensity, because no two studies utilized the same intervention. Because of limited descriptions and differences in approach, they were unable to identify the most effective intervention components.

In a review on prevention of healthcare-associated infection,2 investigators identified 16 different combinations of components across studies. Sufficient similarities were found to allow investigators to group strategies by their components. They designated organizational change and provider education as base strategies because they were found in a majority of intervention bundles.

A review on medication adherence4 categorized interventions by a previously developed taxonomy, and noted those that were tailored. The presence or absence of tailoring was not used to stratify the analysis, likely related to the fact that they were often single studies of a diversity of interventions. As a result in the analysis of features of effective interventions, the effect of tailoring could not be explored. This review, however, did describe characteristics of interventions, related to the target, mode of delivery, intensity, duration and components. However, because of the diversity of interventions and limited descriptions of both the intervention and characteristics, investigators were unable to compare these features and make inferences about their potential impact on outcomes. While recognizing the potential influences of these intervention characteristics, they were unable to do more than describe what was reported in the primary literature.

## Outcome Selection and Measurement

Reviews included behavioral outcomes in reviews as intermediate outcomes. For example in a review of treatments for disruptive behaviors,8 behavioral outcomes such as aggressive behavior, fighting and property destruction, were proximal to the functional outcomes of family functioning, school performance, and quality of life. In a review of smoking cessation interventions included intermediate outcomes related to behavior change:15 cessation, relapse, and continuous abstinence, in addition to clinical outcomes such as asthma, hospitalization, and pre-term birth.

Some reviews required reporting of an objective clinical outcome in addition to the behavioral outcome for inclusion into the body of evidence. Presumably this was done to ensure that the more distal outcomes could be attributed to the impact of the intervention on the desired behavior change. For example in a review on diabetes strategies,16 investigators excluded studies that did not include both outcomes of patient adherence, provider/patient understanding, satisfaction, or self-efficacy, and a measure of disease control or adherence. They also excluded all self-reported adherence measures for providers. In another review on adult weight gain prevention,13 investigators had planned to include the intermediate outcomes of knowledge, attitude, and skills when a weight outcome was also reported.

## Quality Assessment of Individual Studies

To assess individual study quality, authors drew from existing resources including the EPC program methods guidance, USPSTF methods, Cochrane methods guidance, Newcastle-Ottawa Scale, and CRD. Most times qualitative research included to inform descriptive questions such as issues as barriers, usability, and context, were not formally assessed.2,9

Authors adapted available quality assessment tools and drew from previously adapted tools for the program using varied approaches. In the HAI prevention report,2 authors adapted a quality assessment tool from a previous EPC review on HAI prevention and included additional criteria were drawn from the RTI Item Bank for assessing observational studies. Investigators developed a new tool and used it across a series of autism reviews.5,17 When authors create new tools or revisions to new tools, one-off approaches may lack consistent interpretations and validity.

## Synthesis

Many reviews that had a diversity of study designs conducted a qualitative synthesis. In select reviews, lower quality studies were excluded from the body of evidence.4,18

In a review of smoking cessation15 in pregnancy and post-partum, investigators were able to assess the impact of individual intervention components. They used a logistic mixed effects model that estimated quit rate across studies. They were able to evaluate some components individually (such as feedback information and peer support) but could not assess counseling as it was commonly provided across intervention and control arms.

In a review on patient safety practices,3 investigators examined the evidence for implementation and cost, and qualitatively synthesized for themes about effective implementation. They categorized implementation difficulty as difficult, not difficult, and moderate; and cost as low, medium, and high. These elements, in addition to assessment of effectiveness, were included to help with decisionmaking.

## SOE

Most reviews graded the strength of evidence using EPC methods guidance. SOE was generally not graded for descriptive key questions, such as description of intervention components and implementation features.7,19

## Appendix B References

1 Hussey P, Mulcahy A, Schnyer C, et al. Bundled Payment: Effects on Health Care Spending and Quality. AHRQ Publication No. 12-E007-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Rothenberg BM, Marbella A, Pines E, et al. Prevention of Healthcare-Associated Infections. Closing the Quality Gap: Revisiting the State of the Science. AHRQ Publication No.12(13)-E012-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Shekelle PG, Wachter RM, Pronovost PJ, et al. Making Health Care Safer II: An Updated Critical Analysis of the Evidence for Patient Safety Practices. AHRQ Publication No.13-E001-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Viswanathan M, Golin CE, Jones CD, et al. Medication Adherence Interventions: Comparative Effectiveness. AHRQ Pub. No.12-E010-1. Agency for Healthcare Research and Quality. September. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
5 Warren Z, Veenstra-VanderWeele J, Stone W, et al. Therapies for children with autism spectrum disorders. AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Totten AM, Wagner J, Tiwari A, et al. Public reporting as a quality improvement strategy. Closing the quality gap: revisiting the state of the science. Evidence Report/Technology Assessment. 2012;(208).
7 Williams J, Jackson G, Powers B, et al. The Patient-Centered Medical Home. AHRQ Publication No.12-E008-1. Rockville, MD. July. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
8 Psychosocial and pharmacologic interventions for disruptive behavior disorder. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
9 Jimison H, Gorman P, Woods S, et al. Barriers and drivers of health information technology use for the elderly, chronically ill, and underserved. AHRQ Publication No. 09-E004. Rockville, MD. Agency for Healthcare Research and Quality. November. 2008. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
10 Forman-Hoffman V, Knauer S, McKeeman J, et al. Child and Adolescent Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Trauma Other Than Maltreatment or Family Violence. AHRQ Publication No.13-EHC054-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Bravata DM, Sundaram V, Lewis R, et al. A Critical Analysis of Quality Improvement Strategies (Vol. 5: Asthma Care). AHRQ Publication No. 04(07)-0051-5. Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
12 Screening and Behavioral Counseling Interventions in Primary Care to Reduce Alcohol Misuse. U.S. Preventive Services Task Force. 2012. http://www.uspreventiveservicestaskforce.org/uspstf12/alcmisuse/alcmisusefinalrs.htm. August 2014.
13 Gierisch JM, Nieuwsma JA, Bradford DW, et al. Interventions to improve cardiovascular risk factors in people with serious mental illness. AHRQ Publication No. 13-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
14 Sun X, Patnode CD, Williams C, et al. Interventions to Improve Patient Adherence to Hepatitis C Treatment: Comparative Effectiveness. AHRQ Publication NO. 13-EHC009-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Likis FE, Andrews JC, Fonnesbeck CJ, et al. Smoking Cessation Interventions in Pregnancy and Postpartum Care. AHRQ Publication No.14-E001-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2014. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Shojania KG, Ranji SR, Shaw LK, et al. A Critical Analysis of Quality Improvement Strategies (Vol. 2: Diabetes Care). Rockville, MD. Agency for Healthcare Research and Quality. September. 2004. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
17 Taylor JL, Dove D, Veenstra-VanderWeele J, et al. Interventions for adolescents and young adults with autism spectrum disorders. AHRQ Publication No. 12-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Hutfless S, Maruthur NM, Wilson RF, et al. Strategies to Prevent Weight Gain Among Adults. AHRQ Publication No. 13-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
19 Medication Therapy Management. Rockville, MD. Agency for Healthcare Research and Quality. July. 2013. http://effectivehealthcare.ahrq.gov/reports/final.cfm.