# AHRQ EHC Program Reports Including Studies of Behavior Change Interventions

Report | Examples of Behavioral Interventions Addressed
Interventions to Modify Health Care Provider Adherence to Asthma Guidelines (May 2013)1 | Audit and feedback, education, organizational change
Primary Care Management of Abnormal Uterine Bleeding (March 2013)2 | Behavioral and lifestyle interventions--exercise, diet
Breathing Exercises and/or Retraining Techniques in the Treatment of Asthma: Comparative Effectiveness (September 2012)3 | Breathing techniques
Treatment for Depression After Unsatisfactory Response to SSRIs (April 2012)4 | CBT and other psychotherapies
Noncyclic Chronic Pelvic Pain Therapies for Women: Comparative Effectiveness (January 2012)5 | CBT, comprehensive therapy
Comparative Effectiveness of Psychological Treatments and Pharmacological Treatments for Adults with Posttraumatic Stress Disorder (April 2013)6 | CBT, exposure therapy, narrative therapy, cognitive processing, other psychotherapies, relaxation
Child Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Maltreatment (April 2013)7 | CBT, family therapy, psychotherapy, hypnosis
Interventions for the Prevention of Posttraumatic Stress Disorder (PTSD) in Adults After Exposure to Psychological Trauma (April 2013)8 | CBT, psychological interventions, hypnosis, education
Interventions for Adolescents and Young Adults with Autism Spectrum Disorders (August 2012)9 | CBT, social skills, job training
Screening, Behavioral Counseling, and Referral in Primary Care to Reduce Alcohol Misuse (July 2012)10 | Counseling, support
Screening and Diagnosing Gestational Diabetes Mellitus (November 2012)11 | Diet modification
Comparative Effectiveness of Bariatric Surgery and non-Surgical Therapy in Adults with Metabolic Conditions and Body Mass Index of 30 to 34.9 kg/m2 (June 2013)12 | Diet, exercise, counseling, education
Recurrent Nephrolithiasis in Adults: Comparative Effectiveness of Preventive Medical Strategies (July 2012)13 | Dietary therapy
Comparative Effectiveness of Therapies for Children with Autism Spectrum Disorders (April 2011)14 | Early intervention, CBT, social skills, play and interaction-focused interventions
Critical Analysis of the Evidence for Patient Safety Practices (December 2011)*15 | Education, audit and feedback
Closing the Quality Gap Series: Prevention of Health Care-Associated Infections (November 2012)16 | Education, audit and feedback, organizational change
Closing the Quality Gap Series: Medication Adherence Interventions: Comparative Effectiveness (September 2012)17 | Education, coaching, social support
Long-Term Care for Older Adults: A Review of Home and Community-Based Services Versus Institutional Care (November 2012)18 | Education, counseling
Closing the Quality Gap Series: Medication Adherence Interventions: Comparative Effectiveness (September 2012)*17 | Education, counseling, behavioral interventions, reminders, rewards, etc., variation in usual care,
Strategies to Prevent Weight Gain Among Adults (March 2013)19 | Education, exercise, diet
Strategies to Reduce Cesarean Birth in Low-Risk Women (October 2012)20 | Education, relaxation, social support, doula, audit and feedback
Quality Improvement, Diabetes (September 2004)*21 | Education, self-management
Comparison of Characteristics of Nursing Homes and Other Residential Long-Term Care Settings for People with Dementia (October 2012)22 | Education, storytelling, group therapy, sensory stimulation, personalized care protocols
Literacy Interventions and Outcomes, Update (March 2011)23 | Education, support
Treatment to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis: Update of a 2007 Report (March 2012)24 | Exercise
Comparative Effectiveness of Treatments to Prevent Fracture in Men and Women with Low Bone Density or Osteoporosis Fractures (December 2007)25 | Exercise
Treatment for Restless Leg Syndrome (November 2012)26 | Exercise
Treatment Strategies for Patients with Peripheral Artery Disease (May 2013)27 | Exercise
Exercise-induced Bronchoconstriction and Asthma (January 2010)28 | Exercise warm up
Physical Therapy Interventions for Knee Pain Secondary to Osteoarthritis (November 2012)29 | Exercise, tai chi
Interventions for Feeding and Nutrition in Cerebral Palsy (March 2013)30 | Feeding interventions, positioning
Traumatic Brain Injury and Depression (April 2011)31 | Individual/group psychotherapy, neuropsychological rehabilitation, community-based rehabilitation, complementary and alternative medicine
Childhood Obesity Prevention Programs: Comparative Effectiveness Review and Meta-Analysis (June 2013)32 | Lifestyle, weight management education
Multidisciplinary Postacute Rehabilitation for Moderate to Severe Traumatic Brain Injury in Adults (June 2012)*33 | Multidisciplinary interventions
Health Information Technology Use for the Elderly, Chronically Ill, and Underserved (November 2008)34 | Online support, health games, self-monitoring systems
Closing the Quality Gap Series: Quality Improvement Measurement of Outcomes for People with Disabilities (October 2012)35 | Patient and provider education
Closing the Quality Gap Series: Quality Improvement Interventions to Address Health Disparities (August 2012)36 | Patient and provider education; multicomponent interventions
Transition of Care for Acute Stroke and Myocardial Infarction Patients from Hospitalization to Rehabilitation, Recovery and Secondary Prevention (October 2011)37 | Patient education
Enhancing the Use and Quality of Colorectal Cancer Screening (February 2010)38 | Patient education
Outcomes of Community Health Worker Interventions, Outcomes (June 2009)39 | Patient education
Diabetes Education for Children with Type 1 Diabetes Mellitus and their Families (April 2008)40 | Patient education, CBT, family therapy, motivational interviewing
Antibiotic Prescribing Behavior, Quality Improvement (January 2006)41 | Patient education, clinician education, audit and feedback
Closing the Quality Gap Series: Prevention of Healthcare-Associated Infections (November 2012)16 | Patient education, provider education, audit and feedback
Asthma Care, Quality Improvement (January 2007)43 | Patient education, provider education, audit and feedback; brief discussion of heterogeneity, need for theoretical grounding for interventions
Nonsurgical Treatments for Urinary Incontinence in Adult Women: Diagnosis and Comparative Effectiveness (April 2012)44 | Pelvic floor muscle training, vaginal cones, bladder training, weight loss
Comparative Effectiveness of Diagnosis and Treatment of Obstructive Sleep Apnea in Adults (August 2011)*45 | Physical therapy, weight loss
Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears (July 2010)*46 | Postoperative rehabilitation, exercise, manual therapy, cortisone injections, acupuncture, other treatments and modalities typically delivered by physical therapists, osteopaths and chiropractors.
Practice-Based Interventions Addressing Concomitant Depression and Chronic Medical Conditions in the Primary Care Setting (August 2012)47 | Problem solving therapy
Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment (October 2011)48 | Psychotherapy
Child and Adolescent Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Trauma Other Than Maltreatment or Family Violence (February 2013)49 | Psychotherapy, CBT, family therapy
Pain Management Interventions for Hip Fracture (May 2011)50 | Rehabilitation, traction
Hypertension, Quality Improvement (January 2005)*51 | Reminders, education, incentives
Self-Measured Blood Pressure Monitoring: Comparative Effectiveness (January 2012)52 | Self-monitoring
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults (September 2011)*53 | Socio-environmental therapy, interpersonal psychotherapy , psychotherapy, cognitive therapy, CBT
Closing the Quality Gap Series: Improving Health Care and Palliative Care for Advanced and Serious Illness (October 2012)54 | Support, counseling, communication
Localized Prostate Cancer Surveillance (December 2011)55 | Surveillance
Treatment for Overactive Bladder in Women (August 2009)56 | Training, biofeedback
Interventions to Improve Cardiovascular Risk Factors in People with Serious Mental Illness (April 2013)57 | Weight management, lifestyle interventions
Effectiveness of Weight Management Programs in Children and Adolescents (September 2008)*58 | Weight management, lifestyle interventions

Note: CBT = Cognitive Behavioral Therapy

## Appendix A References

1 Okelo SO, Butz AM, Sharma R, et al. Interventions To Modify Adherence to Asthma Guidelines. Rockville, MD. 2013. May. Report No.: AHRQ Publication No. 13-EHC022-EF Contract No.: 95. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Hartmann KE, Jerome RN, Lindegren ML, et al. Primary care management of abnormal uterine bleeding. Rockville, MD. Agency for Healthcare Research and Quality. 2013. March. Report No.: No. 13-EHC025-EF. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
3 O'Connor E, Patnode CD, Burda BU, et al. Breathing exercises and/or retraining techniques in the treatment of asthma: Comparative effectiveness. Rockville, MD. Agency for Healthcare Research and Quality. 2012. September. Report No.: No. 12-EHC092-EF Contract No.: 71. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Santaguida PL, MacQueen G, Keshavarz H, et al. Treatment for depression after unsatisfactory response to SSRIs. Rockville, MD. Agency for Healthcare Research and Quality. 2012. April. Report No.: No. 12-EHC050-EF Contract No.: 62. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
5 Andrews J, Yunker A, Reynolds WS, et al. Noncyclic chronic pelvic pain therapies for women: comparative effectiveness. Rockville, MD. Agency for Healthcare Research and Quality. 2012. January. Report No.: Contract No.: 41. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
6 Jonas DE, Cusack K, Forneris CA, et al. Psychological and pharmacological treatments for adults with posttraumatic stress disorder (PTSD). Rockville, MD. Agency for Healthcare Research and Quality. 2013. April. Report No.: No. 13-EHC011-EF Contract No.: 92. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
7 Fraser JG, Lloyd SW, Murphy RA, et al. Child exposure to trauma: comparative effectiveness of interventions addressing maltreatment. Rockville, MD. Agency for Healthcare Research and Quality. 2013. No. 13-EHC002-EF Contract No.: 89. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
8 Gartlehner G, Forneris CA, Brownley KA, et al. Interventions for the prevention of posttraumatic stress disorder (PTSD) in adults after exposure to psychological trauma. Rockville, MD. Agency for Healthcare Research and Quality. 2013. April. Report No.: Contract No.: 109. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
9 Taylor JL, Dove D, Veenstra-VanderWeele J, et al. Interventions for adolescents and young adults with autism spectrum disorders. Rockville, MD. 2012. August. Report No.: AHRQ Publication No. 12-EHC063-EF Contract No.: 65. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
10 Jonas DE, Garbutt JC, Brown JM, et al. Screening, behavioral counseling, and referral in primary care to reduce alcohol misuse. Rockville, MD. Agency for Healthcare Research and Quality. 2012. July. Report No.: No. 12-EHC055-EF Contract No.: 64. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Hartling L, Dryden DM, Guthrie A, et al. Screening and diagnosing gestational diabetes mellitus. Rockville, MD. Agency for Healthcare Research and Quality. 2012. October. Report No.: No. 12(13)-E021-EF Contract No.: 210. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
12 Maglione MA, Gibbons MM, Livhits M, et al. Bariatric Surgery and Nonsurgical Therapy in Adults With Metabolic Conditions and a Body Mass Index of 30.0 to 34.9 kg/m^2^. 2013. June. Report No.: AHRQ Publication 12(13)-EHC139-EF. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Fink HA, Wilt TJ, Eidman KE, et al. Recurrent nephrolithiasis in adults: comparative effectiveness of preventive medical strategies. Rockville, MD. Agency for Healthcare Research and Quality. 2012. July. Report No.: No. 12-EHC049-EF Contract No.: 61. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
14 Warren Z, Veenstra-VanderWeele J, Stone W, et al. Therapies for children with autism spectrum disorders. Rockville, MD. 2011. April. Report No.: AHRQ Publication No. 11-EHC029-EF Contract No.: 26. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Critical analysis of the evidence for patient safety practices. Rockville, MD. Agency for Healthcare Research and Quality. 2011. November. Report No. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Rothenberg BM, Marbella A, Pines E, et al. Prevention of Healthcare-Associated Infections. Closing the Quality Gap: Revisiting the State of the Science. Rockville, MD. 2012. AHRQ Publication No. 12(13)-E012-EF Contract No.: 208. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
17 Viswanathan M, Golin CE, Jones CD, et al. Medication Adherence Interventions: Comparative Effectiveness. 2012. September. Report No.: AHRQ Pub. No. 12-E010-1. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Wysocki A, Butler M, Kane RL, et al. Long-term care for older adults: a review of home and community-based services versus institutional care. Rockville, MD. Agency for Healthcare Research and Quality. 2012. November. Report No.: No. 12(13)-EHC134-EF Contract No.: 81. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
19 Hutfless S, Maruthur NM, Wilson RF, et al. Strategies to Prevent Weight Gain Among Adults. Rockville, MD. 2013. March. Report No.: AHRQ Publication No. 13-EHC029-EF Contract No.: 97. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
20 Hartmann KE, Andrews JC, Jerome RN, et al. Strategies to reduce cesarean birth in low-risk women. Rockville, MD. Agency for Healthcare Research and Quality. 2012. October. Report No.: No. 12(13)-EHC128-EF Contract No.: 80. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Coffey RM, Matthews TL, McDermott K. Diabetes care quality improvement: a resource guide for state action. Rockville, MD. Agency for Healthcare Research and Quality. 2004. September. Report No.: No. 04-0072. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
22 Zimmerman S, Anderson W, Brode S, et al. Comparison of characteristics of nursing homes and other residential long-term care settings for people with dementia. Rockville, MD. Agency for Healthcare Research and Quality. 2012. October. Report No.: No. 12(13)-EHC127-EF Contract No.: 79. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
23 Berkman ND, Sheridan SL, Donahue KE, et al. Health literacy and interventions and outcomes: an updated systematic review. Rockville, MD. Agency for Healthcare Research and Quality. 2011. March. Report No.: No. 11-E006 Contract No.: 199. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
24 Crandall CJ, Newberry SJ, Diamant A, et al. Treatment to prevent fractures in men and women with low bone density or osteoporosis: update of a 2007 report. Rockville, MD. Agency for Healthcare Research and Quality. 2012. March. Report No.: No. 12-EHC023-EF Contract No.: 53. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
25 MacLean C, Alexander A, Carter J, et al. Comparative effectiveness of treatments to prevent fractures in men and women with low bone density. Rockville, MD. Agency for Healthcare Research and Quality. 2007. December. Report No.: No. 08-EHC008-EF Contract No.: 12. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
26 Wilt TJ, MacDonald R, Ouellette J, et al. Treatment for restless legs syndrome. Rockville, MD. Agency for Healthcare Research and Quality. 2012. November. Report No.: No. 12(13)-EHC147-EF Contract No.: 86. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
27 Jones WS, Schmit KM, Vemulapalli S, et al. Treatment strategies for patients with peripheral artery disease. Rockville, MD. Agency for Healthcare Research and Quality. 2013. May. Report No.: No. 13-EHC090-EF Contract No.: 118. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
28 Dryden DM, Spooner CH, Stickland MK, et al. Exercise-induce bronchoconstriction and asthma. Rockville, MD. Agency for Healthcare Research and Quality. 2010. January. Report No.: No. 10-E001 Contract No.: 189. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
29 Shamliyan TA, Wang S-Y, Olson-Kellogg B, et al. Physical therapy interventions for knee pain secondary to osteoarthritis. Rockville, MD. Agency for Healthcare Research and Quality. 2012. November. Report No.: No. 12(13)-EHC115-EF Contract No.: 77. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
30 Ferluga ED, Archer KR, Sathe NA, et al. Interventions for Feeding and Nutrition in Cerebral Palsy. Rockville, MD. 2013. March. Report No.: AHRQ Publication No. 13-EHC015-EF Contract No.: 94. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
31 Guillamondegui OD, Montgomery SA, Phibbs FT, et al. Traumatic brain injury and depression. Rockville, MD. Agency for Healthcare Research and Quality. 2011. April. Report No.: No. 11-EHC017-EF Contract No.: 25. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
32 Wang Y, Wu Y, Wilson RF, et al. Childhood obesity prevention programs: comparative effectiveness review and meta-analysis. Rockville, MD. 2013. June. Report No.: AHRQ Publication No. 13-EHC081-EF Contract No.: 115. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
33 Brasure M, Lamberty GJ, Sayer NA, et al. Multidisciplinary postacute rehabilitation for moderate to severe traumatic brain injury in adults. Rockville, MD. Agency for Healthcare Research and Quality. 2012. June. Report No.: No. 12-EHC101-EF Contract No.: 72. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
34 Jimison H, Gorman P, Woods S, et al. Barriers and drivers of health information technology use for the elderly, chronically ill, and underserved. Rockville, MD. Agency for Healthcare Research and Quality. 2008. November. Report No.: No. 09-E004 Contract No.: 175. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
35 Butler M, Kane RL, Larson S, et al. Quality improvement measurement of outcomes for people with disabilities Closing the Quality Gap: Revisiting the State of the Science. Rockville, MD. Agency for Healthcare Research and Quality. 2012. October. Report No.: No. 12(13)-E013-EF Contract No.: 208. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
36 McPheeters ML, Kripalani S, Peterson NB, et al. Quality improvement interventions to address health disparities Closing the Quality Gap: Revisiting the State of the Science. Rockville, MD. Agency for Healthcare Research and Quality. 2012. August. Report No.: No. 12-E009-EF Contract No.: 208. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
37 Olson DM, Bettger JP, Alexander KP, et al. Transition of care for acute stroke and myocardial infarction patients. Rockville, MD. Agency for Healthcare Research and Quality. 2011. October. Report No.: No. 11(12)-E011 Contract No.: 202. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
38 Holden DJ, Harris R, Porterfield DS, et al. Enhancing the use and quality of colorectal cancer screening. Rockville, MD. Agency for Healthcare Research and Quality. 2010. February. Report No.: No. 10-E002 Contract No.: 190. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
39 Viswanathan M, Kraschnewski J, Nishikawa B, et al. Outcomes of community health worker interventions. Rockville, MD. Agency for Healthcare Research and Quality. 2009. June. Report No.: No. 09-E014 Contract No.: 181. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
40 Couch R, Jetha M, Dryden DM, et al. Diabetes education for children with Type 1 Diabetes Mellitus and their families. Rockville, MD. Agency for Healthcare Research and Quality. 2008. April. Report No.: No. 08-E011 Contract No.: 166. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
41 Ranji SR, Steinman MA, Shojania KG, et al. Antibiotic Prescribing Behavior Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Rockville, MD. Agency for Healthcare Research and Quality. 2006. January. Report No.: No. 04(06)-0051-4 Contract No.: 9.4. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
42 Gibbons MC, Wilson RF, Samal L, et al. Impact of consumer health informatics applications. Rockville, MD. Agency for Healthcare Research and Quality. 2009. October. Report No.: No. 09(10)E-019 Contract No.: 188. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
43 Bravata DM, Sundaram V, Lewis R, et al. Asthma Care Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Rockville, MD. Agency for Healthcare Research and Quality. 2007. January. Report No.: No. 04(07)-0051-5 Contract No.: 9.5. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
44 Shamliyan T, Wyman J, Kane RL. Nonsurgical treatments for urinary incontinence in adult women: diagnosis and comparative effectiveness. Rockville, MD. Agency for Healthcare Research and Quality. 2012. April. Report No.: No. 11(12)-EHC074-EF Contract No.: 36. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
45 Balk EM, Moorthy D, Obadan NO, et al. Diagnosis and treatment of obsrtuctive sleep apnea in adults. Rockville, MD. Agency for Healthcare Research and Quality. 2011. July. Report No.: No. 11-EHC052 Contract No.: 32. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
46 Seida JC, Schouten JR, Mousavi SS, et al. Comparative effectiveness of nonoperative and operative treatments for rotator cuff tears. Rockville, MD. Agency for Healthcare Research and Quality. 2010. July. Report No.: No. 10-EHC050-EF Contract No.: 22. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
47 Watson L, Amick HR, Gaynes BA, et al. Practice-based interventions addressing concomitant depression and chronic medical conditions in the primary care settings. Rockville, MD. Agency for Healthcare Research and Quality. 2012. August. Report No.: No. 12-EHC106-EF Contract No.: 75. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
48 Charach A, Dashti B, Carson P, et al. Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-risk Preschoolers; Long-term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment. Rockville, MD. 2011. October. Report No.: AHRQ Publication No. 12-EHC003-EF Contract No.: 44. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
49 Forman-Hoffman V, Knauer S, McKeeman J, et al. Child and Adolescent Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Trauma Other Than Maltreatment or Family Violence. Rockville, MD. 2013. February. Report No.: AHRQ Publication No. 13-EHC054-EF Contract No.: 107. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
50 Abou-Setta AM, Beaupre LA, Jones CA, et al. Pain management interventions for hip fracture. Rockville, MD. Agency for Healthcare Research and Quality. 2011. May. Report No.: No. 11-EHC022-EF Contract No.: 30. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
51 Walsh J, McDonald KM, Shojania KG, et al. Hypertension Care Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Rockville, MD. Agency for Healthcare Research and Quality. 2005. January. Report No.: No. 04-0051-3 Contract No.: 9.3. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
52 Uhlig K, Balk EM, Patel K, et al. Self-measured blood pressure monitoring: comparative effectiveness. Rockville, MD. Agency for Healthcare Research and Quality. 2012. Januar. Report No.: No. 12-EHC002-EF Contract No.: 45. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
53 Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults. Houston, TX. John M. Eisenberg Center for Clinical Decision and Communication Science, Baylor College of Medicine. 2011. September. Report No.: AHRQ Pub. No. 11(12)-EHC056-3 Contract No.: 33. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
54 Improving health care and palliative care for advanced and serious illness Closing the Quality Gap: Revisiting the State of the Science. Rockville, MD. Agency for Healthcare Research and Quality. 2012. October. Report No.: No. 12(13)-E014-1 Contract No.: 208. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
55 Ip S, Dahabreh IJ, Chung M, et al. An evidence review of active surveillance in men with localized prostate cancer. Rockville, MD. Agency for Healthcare Research and Quality. 2011. December. Report No.: No. 12-E003-EF Contract No.: 204. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
56 Hartmann KE, McPheeters ML, Biller DH, et al. Treatment for overactive bladder in women. Rockville, MD. 2009. August. Report No.: AHRQ Publication No. 09-E017 Contract No.: 187. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
57 Gierisch JM, Nieuwsma JA, Bradford DW, et al. Interventions to improve cardiovascular risk factors in people with serious mental illness. Rockville, MD. 2013. April. Report No.: AHRQ Publication No. 13-EHC063-EF Contract No.: 105. http://effectivehealthcare.ahrq.gov/reports/final.cfm.
58 Whitlock EP, O'Connor EA, Williams SB, et al. Effectiveness of weight management programs in children and adolescents. Rockville, MD. 2008. September. Report No.: AHRQ Publication No. 08-E014 Contract No.: 170. http://effectivehealthcare.ahrq.gov/reports/final.cfm.