# Results

## Results of the Literature Search

The literature search process identified 19,127 citations that were deemed potentially relevant to the aims of our overall project (see Figure 1). The search strategy used in all search engines was modeled on that which we used in MEDLINE^®^, with similar search terms (see Appendix B).

Figure 1 Results of the search

Figure 1 graphically details the number of unique articles identified by the searches used (19,127), the number excluded at title review (15,685), the number excluded at abstract review (2,756), and the number excluded through full article screening (2,746), leaving 10 articles eligible for discussion in this review.

In the title review process, we excluded 15,685 citations that clearly did not apply to the aims of our project. In the abstract review process, we excluded 2,756 citations that did not meet one or more of the eligibility criteria (see Methods section for details). At the article inclusion/exclusion phase, we excluded an additional 511 articles that did not meet one or more of the eligibility criteria, leaving 175 articles identified as possible “checklists.” This pool of articles was further reviewed by the senior investigators on the team and 165 were excluded during this process (Figure 1), leaving a total of 10 articles reporting on original guidelines or checklists.

## Description of Applicable Checklists

In this section, we describe the eligible articles in chronological order. For each article we provide details on the format of the reported guideline or checklist, its goal, the methods for development, and any validation data.

Adams, 1992.^26^ To evaluate the completeness of economic analyses in randomized controlled trials, Adams et al. (1992) developed a checklist based substantially on the first edition of the textbook, “Methods for the Economic Evaluation of Health Care Programmes” by Drummond et al., 1987^27^ (Appendix G, Table 1).

Gerard, 1992.^28^ The development of these evaluation criteria incorporated a number of views, “all from individuals with experience in the field.” The criteria used by Drummond et al., 1987^27^ were reference points on the basis of which Gerard revised some and added others. The criteria that evolved from that process were then sent for review by 18 international researchers in the field. Twelve responded with comments and these were taken into consideration. The criteria were tested on a pilot of three cost-utility analyses. The final set of criteria comprised 40 separate judgments to be made per study (Appendix G, Table 2).

Sacristan, 1993.^29^ Sacristan et al. developed a checklist with 12 sections, each of which includes several subsections, resulting in a total of 40 items. The checklist was devised by analyzing “the most relevant studies on the subject.” After evaluating the corresponding subsections, each section is to be labelled as “correct,” “acceptable,” “doubtful,” “incorrect,” or “not applicable” (Appendix G, Table 3).

Clemens, 1995.^30^ In January 1995, the Pharmaceutical Research and Manufacturers of America (PhRMA) adopted a voluntary set of principles to provide guidance for its member companies on the conduct and evaluation of pharmacoeconomic research. The principles were prepared by a working group of pharmacoeconomic scientists from the Task Force on the Economic Evaluation of Pharmaceuticals. The principles were reviewed by a panel of academic experts and outside reviewers at each stage of their development. The PhRMA document consists of a set of broad principles that aim to foster high quality pharmacoeconomic research. While specific recommendations are offered in those methodological areas for which general agreement exists, no attempt was made to force a consensus for those methodological issues which, at the time, were yet to be resolved (and some remain unresolved.) (Appendix G, Table 4).

The U.S. Panel.31-33 In the United States, the Panel on Cost-Effectiveness in Health and Medicine34 reviewed the theoretical foundations of cost-effectiveness analysis, current practices, alternative methods, published critiques of cost-effectiveness analyses and criticisms of related general methods and reporting practices. The panel developed recommendations through two and a half years of discussions. Comments on preliminary drafts were solicited from federal government methodologists, health agency officials and academic methodologists (Appendix G, Table 5).

The British Medical Journal (BMJ) Checklist.35 The BMJ set up a working party to develop a quality assessment checklist for use by both referees and authors. Drafts of the checklist were transmitted to health economists and journal editors and were debated at the biannual meeting of the U.K. Health Economists' Study Group in January 1996. The final checklist was based on a broad consensus and contains 35 items under three headings: study design, data collection, and analysis and interpretation of results. This checklist concentrates on full economic evaluations but could also be used for partial economic evaluations, or reports and commentaries on economic evaluations. If items are not applicable to a specific study, a “not appropriate” (NA) response can be stated. The working party admitted that it is not possible to address all the points in an article and that authors can, for example, refer the reader to other published sources (Appendix G, Table 6).

The Pediatrics Quality Appraisal Questionnaire (PQAQ).25 The PQAQ is longer and more detailed than other checklists, and it has been formally validated. It contains 57 items that map into 14 domains. The PQAQ was developed specifically to evaluate the quality of economic appraisals in pediatrics. The authors claim that 9 of the 47 questions are unique to the pediatric population. Scrutiny of these questions suggests this is not the case, however, because it is easy to generalize many of these questions to other populations. Of the 57 questions, 46 items have response options that are scored: 0 if the article fails the criterion or is impossible to judge; 0.5 if the criterion is met partially; or 1 if the criterion is met fully. Ten items refer to descriptive information about the study. The final item is an overall assessment of the quality of the study. This is scored on a 6 point Likert scale, where 1 means excellent and 6 means worthless. A panel of seven experts in health economic evaluation independently assessed potential items for their importance, the clarity of the questions, and the appropriateness of the response categories. Although each of the 46 quantitative items is given a numerical score, the experts involved in the development of the PQAQ cautioned against computing a summary score. Their argument was that each domain was important and a high score on one domain should not be allowed to mask a low score on other domains (Appendix G, Table 7).

The Quality of Health Economic Studies (QHES) List.24A steering committee comprised of five experts in the field of health economics and three investigators developed a checklist for economic evaluations from a literature search using Medline, Healthstar, and the Cochrane databases. From existing guidelines and checklists, the committee selected 16 criteria with a “Yes” or “No” format. The selection was made by consensus. Then, weights for each criterion were estimated using a general linear regression (random effects) based on data collected from a conjoint analysis survey of 120 international health economists. The scale was then validated prospectively using a third group of health economists who compared their subjective global assessment of a sample of studies (using a visual analog scale) with scores obtained by the QHES. A study either meets or fails to meet each criterion, thus scoring either the full weighted value or zero for each question. The perfect score for a study is 100 and the lowest score is 0 (Appendix G, Table 8).

The Consensus on Health Economic Criteria (CHEC) List.23 This is a single checklist, one of the three checklists published by the University of York Centre for Review and Dissemination. An initial item pool divided in 19 categories was first developed by performing a literature search from Medline, Psychlit, Econlit, the Cochrane Library, and the National Health Service Economic Evaluation Databases (NHS EED). The criteria list was then created using the Delphi method. This method made use of a panel of experts on a specific topic to reach a consensus. In a first round, international experts were asked to give their opinion on the categories and the items selected from the literature search. Comments and the resulting list were redistributed among experts until a consensus was reached. Three rounds were sufficient to obtain the final criteria list. More details on the method used can be found in the literature (Evers, 2005^23^). The list contains 19 yes or no questions. Authors recommended that if not enough information was available in the article or in other published material to answer a question, a “No” response should be given. It should be noted that this list was not created to analyze the quality of economic evaluations based on modeling studies (Appendix G, Table 9).

A Checklist to Frame Health Technology Assessments for Resource Allocation Decisions. The authors reviewed published literature to identify factors that should be considered when framing health technology assessments for resource allocation decisions (Grutters, 2011^36^). The checklist contains 11 factors and was finalized in collaboration with clinicians and policy makers (Appendix G, Table 10).

Table 1 shows the number of times the ten checklists have been cited. This provides an indication of the use and importance of each checklist. Although the Drummond and U.S. Panel checklists have been cited most frequently, they were also published over a decade ago, whereas some of the other checklists were published more recently.

Table 1 Number of citations through March 2012 that cited published checklists on the conduct and reporting of economic evaluations in health care

| Google Scholar | SCOPUS | Web of Science
Adams ME et al. Economic analysis in randomized control trials. Med Care. 1992; 30: 231-43.^26^ | 151 | 100 | 125
Gerard K. Cost-utility in practice: a policymaker's guide to the state of the art. Health Policy. 1992; 21: 249-79.^28^ | 112 | 68 | 85
Sacristán JA, Soto J, Galende I. Evaluation of pharmacoeconomic studies: utilization of a checklist. Ann Pharmacother. 1993; 27: 1126-33.^29^ | 70 | 52 | 47
Clemens K et al. Methodological and conduct principles for pharmacoeconomic research. Pharmaceutical Research and Manufacturers of America. Pharmacoeconomics. 1995; 8: 169-74.^30^ | Not listed | 52 | 44
Russell LB et al. The role of cost-effectiveness analysis in health and medicine. Panel on Cost-Effectiveness in Health and Medicine. JAMA. 1996; 276: 1172-7.^31^ | 6378 | 624 | 600
Siegel JE et al. Recommendations for reporting cost-effectiveness analyses. Panel on Cost-Effectiveness in Health and Medicine. JAMA. 1996; 276: 1339-41.^33^ | 660 | 601 | 548
Weinstein MC et al. Recommendations of the Panel on Cost-effectiveness in Health and Medicine. JAMA. 1996; 276: 1253-8.^32^ | 1422 | 1128 | 1074
Drummond MF, Jefferson TO. Guidelines for authors and peer reviewers of economic submissions to the BMJ. The BMJ Economic Evaluation Working Party. BMJ. 1996; 313: 275-83.^35^ | 907 | 706 | 626
Ungar WJ, Santos MT. The Pediatric Quality Appraisal Questionnaire: an instrument for evaluation of the pediatric health economics literature. Value Health. 2003; 6: 584-94.^25^ | 13 | 8 | 7
Chiou CF et al. Development and validation of a grading system for the quality of cost-effectiveness studies. Med Care. 2003; 41: 32-44. (Quality of Health Economics Studies list)24 | 69 | 55 | 43
Evers S et al. Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care. 2005; 21: 240-5.^39^ | 100 | 78 | 63
Grutters JPC et al. Bridging trial and decision: a checklist to frame health technology assessments for resource allocation decisions. Value in Health. 2011; 14: 777-84.^36^ | 2 | 1 | 1

## Comparison of Checklists

### Similarities and Differences

Table 2 compares the checklists using the most recent checklist (the CHEC List)23 as the reference point. Table 3 details the background characteristics of the checklists. The comparison of instruments showed that they mainly analyze similar items. However, only one item was a criterion in all of the checklists: perspective. In addition, 7 criteria appeared in 11 or more of the checklists: choice of alternatives; perspective; outcome identification; outcome measurement; adjustment for time variation; sensitivity and uncertainties; and incremental analysis. Thus, a strong consensus seemed to exist about some important indicators of quality. On the other hand, four items appeared in five or less of the checklists, suggesting a lack of consensus about their importance: economic identification, outcome valuation, independence of investigators, and ethics and distribution of effects.

Table 2 Comparison of the contents of published checklists for the conduct and reporting of economic evaluations in health care

Criterion | Adams, 1992^26^ | Gerard 1992^28^ | Sacristan, 1993^29^ | Clemens, 1995^30^ | Gold, 1996^34^ | Drummond, 1996^35^ | Ungar, 2003^25^ | Chiou, 2003^24^ | Evers, 2005^23^ | Grutters, 2011^36^ | SUM
Description of the target population | | | X | X | X | X | X | | X | X | 7
Choice of alternatives | X | | X | X | X | X | X | | X | X | 8
Economic study question | | X | X | X | | X | X | X | X | | 7
Economic study design | X | | X | | X | X | X | X | X | | 7
Follow up period | | | X | X | X | | X | X | X | | 6
Perspective | X | X | X | X | X | X | X | X | X | X | 10
Economic identification | X | | | X | | X | X | | X | | 5
Economic measurement | X | X | X | | | X | X | X | X | | 7
Economic valuation | X | X | | | | X | X | | X | X | 6
Outcome identification | X | | | X | X | X | X | X | X | X | 8
Outcome measurement | X | X | X | | X | X | X | X | X | | 8
Outcome valuation | | X | | | | X | X | | X | | 4
Adjustment for time variation | X | X | X | X | X | X | X | | X | X | 9
Sensitivity and uncertainties | X | X | X | X | X | X | X | X | X | | 9
Presentation of results | | X | X | | X | X | X | X | X | | 7
Generalizability of results | | X | | X | X | X | X | | X | | 6
Incremental analysis | X | | X | X | X | X | X | X | X | | 8
Independence of investigators | | | | | | | X | X | X | | 3
Ethics and distribution of effects | X | | X | | X | X | | | X | | 5
Number of the Evers 2005 criteria included in the checklist | 12 | 10 | 13 | 11 | 13 | 17 | 18 | 11 | 19 | 6
Total number of criteria in the checklist | 20 | 37 | 40 | 21 | 37 | 35 | 57 | 16 | 19 | 11

Note: X indicates that the particular list of criteria that is being described in a column includes a criterion related to the issue described in the row.

Table 3 Summary of the basic characteristics of published checklists on the conduct and reporting of economic evaluations in health care

Adams, 1992 26 | Author Affiliation: The Technology Assessment Group, Department of Health Policy and Management, Harvard School of Public Health, Boston, Massachusetts Year of publication: 1992 Journal: Medical Care Funding: Supported in part by the Alfred P. Sloan Foundation and by grant number HS 05936 from the Agency for Health Care Policy and Research Economic Evaluation: Model-based Target Audience: Investigators using economic analyses in clinical trials Intended use of Checklist: Guidance/Descriptive
Gerard, 1992 28 | Author Affiliation: University of Aberdeen [Gerard] Year of publication: 1992 Journal: Health Policy Funding: N/A Economic Evaluation: Trial-based and model based CUA Target Audience: Policy makers and researchers who use CUAs (not explicitly stated) Intended use of Checklist: Guidance
Sacristan, 1993 29 | Author Affiliation: Lilly, S.A., Avda de la Industrial, Madrid Spain Sacristάm] Hospital Santa Cruz, Liencres, Cantabria [Soto] Ministry of Health, Madrid, Spain [Galende] Year of publication: 1993 Journal: The Annals of Pharmacotherapy Funding: N/A Economic Evaluation: Model based Target Audience: Researchers, journal editors, and audiences when performing, receiving, reading, or accepting a clinical evaluation study Intended use of Checklist: Guidance
Clemens, 1995 30 | Author Affiliation: Roche Pharmaceuticals [Clemens] Glaxo, Inc. [Townsend, Oserhaus] Parke-Davis [Luscommbe] Burroughs Wellcome Co [Mauskopf] PhRMA [Babula] Year of publication: 1995 Journal: PharmacoEconomics Funding: PhRMA Task Force on the Economic Evaluation of Pharmaceuticals Economic Evaluation: Model-based Target Audience: Pharmaceutical industry Intended use of Checklist: Guidance
Gold, 1996 34 | Author Affiliation: Primary affiliations: Department of Maternal and Child Health, Harvard School of Public Health ( Siegel), Department of Health Policy and Management, ( Weinstein), Institute for Health, Health Care Policy and Aging Research, Rutgers University (Russell), Office of Disease Prevention and Health Promotion, US Public Health Service (Gold). Secondary Affiliation of all authors: US Panel on Cost-effectiveness in Health and Medicine Year of publication: 1996 Journal: JAMA Funding: N/A Economic Evaluation: CEA (Trial- and Model-based) Target Audience: Decision makers who use CEAs (not explicitly stated who) Intended use of Checklist: Guidance
Drummond, 1996 35 | Author Affiliation: Center for Health Economics, University of York (Drummond) and Ministry of Defence, Army Medical Directorate (Jefferson). The authors wrote the paper on behalf of the BMJ Economic Evaluation Party Year of publication: 1996 Journal: British Medical Journal Funding: N/A (BMJ perhaps since it instituted the working party that engaged in this exercise) Economic Evaluation: Trial- and model-based Target Audience: Specialists, non-specialist readers of economic work ; referees and authors; editors Intended use of Checklist: Guidance
Ungar, 2003 25 | Author Affiliation: Department of Population Health Sciences, The Hospital for Sick Children, Toronto, Ontario, Canada; 2 Department of Health Policy Management and Evaluation, University of Toronto, Toronto, Ontario, Canada Year of publication: 2003 Journal: Value in Health Funding: The Canadian Coordinating Office for Health Technology Assessment, from The Hospital for Sick Children Research Institute, and from in-kind support from The Institute of Health Economics Economic Evaluation: Trial- and model-based Target Audience: Decisionmakers regarding allocation of pediatric interventions and services. Intended use of Checklist: Guidance/Descriptive
Chiou, 2003 24 | Author Affiliation: From Zynx Health Inc., Cedars-Sinai Health System, Beverly Hills, California, Year of publication: 2003 Journal: Medical Care Funding: Supported by TAP Pharmaceutical Products, Inc., Lake Forest, Illinois Economic Evaluation: Model-based Target Audience: Clinical decisionmakers and editors/reviewers of medical journals Intended use of Checklist: Guidance
Evers, 2005 23 | Author Affiliation: Maastricht University (Evers, Ament and Goossens), Vrije Universiteit University Medical Centre(de Vet and van Tulder) Year of publication: 2005 Journal: International Journal of Technology Assessment in Health Care Funding: NS Economic Evaluation: Trial-based Target Audience: Health care professionals, consumers, researchers and policymakers Intended use of Checklist: Guidance
Grutters, 2011 36 | Author Affiliation: Maastricht University (Gutters) Maastricht University Medical Center (Seferina, Tjan-Heijnen, van Kampen, Joore), Dutch Health Care Insurance Board (Goettsch), Year of publication: 2011 Journal: Value in Health Funding: Dutch Organization for Health Research and Development Economic Evaluation: Model-based and Clinical Trials Target Audience: Decisionmakers using health technology assessments for resource allocation Intended use of Checklist: Guidance

CEA: Cost-effectiveness Analysis, CUA: Cost-utility analysis, PhRMA: The Pharmaceutical Research and Manufacturers of America.

Among the checklists, the number of criteria ranged from 11 in the Grutters et al. Checklist36 to Frame Health Technology Assessments for Resource Allocation Decisions, to 57 in the PQAQ (Ungar and Santos, 2003^25^). Comparing the tools to the CHEC23, the PQAQ overlapped the most, with 18 out of the 19 criteria, the exception being “ethics and distribution of effects.” The Grutters checklist36 overlapped the least, matching only 6 out of 19 items, but it had only 11 items in it.

## Reliability and Validity of the Checklists for Assessing the Quality of an Economic Evaluation

Gerard (2000)28 assessed the inter-rater reliability of the BMJ economic submissions checklist when reviewing 43 cost-utility analyses in peer-reviewed English language journals in 1996. Proportional agreement between assessors was over 80 percent.

Gerkens (2008)37 compared the BMJ, CHEC, and the QHES instruments. The analysis was based on a review of nine economic evaluations of the surgical treatment of obesity; each paper was assessed independently by two health economists. To compare instruments, the Spearman rank correlation coefficient was calculated for each assessor. Moreover, the test-retest reliability for each instrument was assessed with the intra-class correlation coefficient (ICC). Finally, the inter-rater agreement for each instrument was estimated at two levels: comparison of the total score of each article by the ICC and comparison of results per item by kappa values. The Spearman's rank correlation coefficient between checklists was usually high (rho > 0.70). Furthermore, test-retest reliability was good for every checklist, that is, 0.98 (95% confidence interval (CI), 0.86 to 0.99) for the BMJ checklist, 0.97 (95% CI, 0.73 to 0.98) for the CHEC list, and 0.95 (95% CI, 0.75 to 0.99) for the QHES instrument. However, inter-rater agreement was poor (kappa < 0.40 for most items and ICC ≤ 0.5).

Au (2008)38 assessed the reliability of the QHES and PQAQ instruments. Thirty published articles were chosen at random from a recent bibliography of economic evaluations in health promotion. The quality of each of these studies was assessed independently by two raters using each of the two checklists. Inter-rater reliability and the agreement between the checklists were measured using an ICC. Inter-rater reliability was excellent for both checklists (ICC 0.81 for the QHES and 0.80 for the PQAQ). Agreement between the checklists varied (ICC = 0.77 for rater 1 and 0.56 for rater 2).

The developers of the PQAQ instrument25 subjected it to an inter-rater and test-retest reliability assessment. Inter-rater reliability was 0.75 (95% CI, 0.66 to 0.81) and test-retest reliability was 0.92 (95% CI 0.71-0.98).

The developers of the QHES checklist25 sent the checklist to 60 individuals with health economics expertise to validate the tool. These individuals rated the quality of three cost-effectiveness studies on a visual analogue scale, and then evaluated each study using the checklist. They used Spearman rho and Wilcoxon tests to assess convergent validity, and analysis of covariance (ANCOVA) to assess discriminant validity. Convergent validity of the checklist and the general score were shown by the results of the Spearman rho (correlation coefficient = 0.78, p< 0.0001) and Wilcoxon test (p = 0.53). The latter result's non-significance was supportive as it suggested a lack of difference in the distribution of the weighted score and the overall score. Discriminant validity was supported by the ANCOVA (F(3,146) = 5.97, p = 0.001).