# Introduction

Guidelines exist for the conduct and review of economic evaluations. In the United States, the systematic review of economic outcomes and the inclusion of economic data in systematic reviews have not been standardized as much as is the case for clinical outcomes.1 The lack of standardization leads to large variation in the quality of economic evaluations and in the use of economic data in systematic reviews.2, 3 This suggests a need to establish some standards in the United States.

Systematic reviews play a critical role in determining the comparative effectiveness of medical interventions and are critical for developing clinical practice guidelines (see Appendix A), efficacy-based coverage decisions, and general health policy.4-7 As such, the processes of searching for and summarizing studies illustrating clinical efficacy and effectiveness have been streamlined in the United States and elsewhere.8, 9 While much work is being done to evaluate the comparative effectiveness of medical interventions,10, 11 the United States has fallen behind international best practices in using economic data in the comparison of medical interventions for the purposes of policymaking.12-16 This is despite calls for integrating cost-effectiveness data routinely in the U.S. health care policy process.17, 18

With increased awareness of the importance of evaluating value for money in health care, the number of published economic evaluations has increased in recent years.19 As more economic analyses are produced, researchers and policymakers need to have methods to synthesize and interpret the results of multiple analyses that address a single issue; systematic review offers a framework for doing this. However, systematic reviews of economic analyses pose special challenges for those who perform reviews and those who use them.20 Traditional techniques of meta-analysis are not appropriate for many economic analyses, which are often syntheses, as in the case of economic modeling studies, and hence should not be combined as one might combine the results of different randomized controlled trials. Instead, systematic reviews of economic modeling studies are most useful for comparing and contrasting how different investigators have chosen to structure their models and estimate key variables. They can also clarify how results differ between studies based on these different assumptions. Identifying sources of variation across studies can help individual decisionmakers determine which studies best apply to their particular settings and can guide future research by identifying areas of uncertainty. Systematic assessment of study quality can help reviewers interpret individual study results. A little over a decade ago, health economists had “not yet developed a formal methodology for reviewing and summing up evidence from individual economic evaluations…or indeed for assessing whether systematic reviews are possible in this context.”21 Today, there are as yet no widely validated methodological criteria to be applied to screening economic studies for inclusion in systematic reviews.22

The difficulty with developing systems to evaluate best practices for conducting economic evaluations is that each economic evaluation faces a potentially unique set of constraints relative to gold standard sets of recommendations. Systems proposed to date have listed criteria for the assessment of economic evaluations, yet have hardly tested comparative rating and weighting of technical criteria. This comparative weighting and the need to determine whether strength in one area can offset a deficiency in another will be critical to the success of the system that is developed. However, it is not clear that systems that will result in a relative ranking of studies that are not perfect can provide anything other than an approximate estimate of the comparative validity of differing results. Nevertheless, there is unquestionably an urgent need for improving the design, analysis and reporting of economic evaluations in health care.

The aim of this paper is to review the strengths and weaknesses of checklists that have been used to evaluate best practices for conducting economic evaluations in health care (Appendix A). These checklists were identified in a systematic review process. We defined checklists as any original listing of specific items that the authors recommended be addressed in the conduct or reporting of an economic evaluation. We focused our attention on the ways in which the checklists define: (1) the criteria for judging that an economic evaluation is of sufficiently high quality to be useful; (2) the importance of different aspects of the evaluation; and (3) the extent to which high quality with respect to one aspect of an economic evaluation can compensate for lower quality with respect to another aspect of the evaluation.