# Technical Expert Panel

Anirban Basu

Department of Medicine, University of Chicago

Chicago, IL

Marthe Gold

City University of New York

New York, NY

Miranda Mugford

University of East Anglis Norwich

Norwich, UK

Peter Neumann

Tufts Medical Center

Boston, MA

Steven Teutsch

Merck & Co., Inc.

West Point, PA