# Acknowledgments

The EPC thanks Brandyn Lau, Dr. Hosne Begum, Todd Noletto, and Beth Barnett for their assistance with the preparation of this report, and Dr. William Lawrence for his valuable insight throughout the project.