# Discussion

The first such checklist for economic evaluation of health care was published in 1974,^40^and some claim that the many efforts at developing guidelines for the conduct and/or reporting of economic evaluations of health care interventions in the 1990s (and 2000s) can be likened to reinventing the wheel.41 However, this statement ignores that most recent guidelines or checklists do represent useful elaborations of Williams' original checklist that take into account many of the methodological developments that have occurred in the interim. Such adaptations should be expected and welcomed.

When economic evaluations are performed or reported poorly it is difficult to incorporate the economic analyses into an overall assessment of cost effectiveness. By using a checklist consisting of a minimum set of items, such as those described in this review, future economic evaluations could become more transparent, informative, and comparable. Although use of a checklist will not guarantee that the results of an economic analysis are valid, it will help to ensure that an economic analysis has the appropriate components. Thus, checklists should be viewed as being complementary to approaches for maximizing the validity of an analysis, such as performing multiple independent analyses and comparing their results, asking an expert panel to review an economic evaluation, or making an economic model publicly available for review.

To remain relevant for cost effectiveness analysis, quality assessment tools must evolve and continue to improve in reliability and validity for a broad spectrum of decision makers. Just as the tools require refinement as experience with them accumulates, users will also need to address the minimal competencies required of those who use the checklists and who make decisions based upon them. The need for refinement comes from an increasing specification of general criteria as well as an understanding of how general criteria often need to be clarified with sub-questions or are partially met and do not lend themselves to simple yes or no answers. Clearly, more work is needed to help decisionmakers obtain reliable and valid assessments of the quality of economic evaluations so that such information can be incorporated into their decisions in an objective and transparent manner.

## What Is Being Measured?

It is now more important than ever to find tools to help filter and interpret enormous amounts of data and thousands of medical literature references. However, checklists can be misapplied if the items do not fit with different types of studies. Inherent flaws in the checklists we reviewed may only be discovered upon repeated use and scrutiny of the results across a wide variety of studies.

Checklists typically cannot separate the quality of reporting from the validity of the design and conduct of a trial. The checklists reviewed in this report have been used primarily as guidance for evaluating the quality of reporting and not as guidance to design studies (although there is no a priori reason why elements of them could not be used for that purpose) or to assess the methodological quality of a study. Many of the checklists contain items that are not directly related to validity but are related to the precision of results (e.g., power calculations) or generalizability (e.g., inclusion and exclusion criteria). When checklist items are weighted and aggregated into a summary score (see discussion below about this), such limitations can be compounded. Despite the appeal of a summary score to measure quality, research has found that the use of summary scores for clinical trials provides unreliable assessments of validity.42 For example, while the objective of the Quality of Health Economic Studies (QHES) tool is to discriminate the quality of studies, many checklist items are more closely related to reporting quality or interpretation of results than internal validity. The checklist places significant weight on issues such as transparency, whether the study objective was clearly stated, and to a lesser extent, the funding source. Important issues related to internal validity were not included in the checklist, such as the nature of randomization and blinding. For example, a cost-effectiveness study that had adequately concealed randomization and was double blinded could receive the same score as a study that inadequately concealed randomization and had no blinding. This is problematic since both poor allocation concealment and blinding have been associated with bias.43 Similarly, the checklist lacks questions to address the internal validity of observational economic evaluations.

It is important to remember that the reliability of a full economic evaluation is in part predicated on its use of reliable effectiveness data. Thus, critical appraisal of an economic evaluation should involve consideration of the sources of bias that may apply to the effectiveness data used in the evaluation.22

## Measured Versus Modeled

In some cases there need to be distinct criteria for evaluating economic data that are generated alongside randomized controlled trials or otherwise measured and data that are the result of modeling. Furthermore, many studies use both methods and those may need a blended set of criteria. Use of the “Drummond checklist”35 and the CHEC list23 is recommended in Cochrane reviews to inform appraisal of the methodological quality of full economic evaluations conducted alongside single effectiveness studies, and also to inform critical appraisal of partial economic evaluations using the subset of applicable checklist items. If the scope of the critical review of health economics studies encompasses relevant economic modeling studies, then assessments of the methodological quality of such studies will need to be informed by a different checklist. The Drummond checklist and CHEC list are relevant but not sufficient for modelling studies. The “Phillips checklist”44 can be used to inform critical appraisal of the methodological quality of economic modeling. Use of this checklist can be supplemented by referring to a published hierarchy of the best available sources to inform each parameter in an economic model.45

The CHEC list is designed for clinical trials and observational studies. Consequently, there is no item on model characteristics. Moreover, this checklist does not require that limitations of the studies, particularly observational studies, be specified. On the other hand, the BMJ checklist and the QHES instruments were mainly adapted to modeling studies. Consequently, the item assessing if details of the model were given would not apply to clinical trials. It could be valuable to have a checklist that can be easily adapted to different study designs with specific subquestions for each design.22

## Scoring Schemes

Quantitative measures of quality allow studies to be ranked according to a quality score. One solution is to apply an equal weight for each item, but this strategy does not allow analysts to take into account the relative importance of each criterion. In part for this reason, another instrument was developed: the QHES,24 a grading system in which weightings differ according to the relative importance of each criterion. No empirical evidence has been generated to validate and describe the generalizability of the scoring system. Further, no scoring scheme has used a criterion like “is there a fatal flaw in the study?” to completely eliminate the study from further consideration. Eliminating studies with fatal flaws would make the entire review process more efficient.

Many checklists do not provide a score to enable the simple comparison among studies. Related to this point, some of these checklists and appraisal criteria assume that each criterion shares an equal weight or level of importance. Thus, it is unclear if current instruments have the capability to discriminate between health economic analyses of high and low quality, and whether users of economic literature without specific expertise are able to derive the needed information from the qualitative instruments. Given that many published studies have been viewed as being of poor quality, it may be more discriminating to use the QHES grading system rather than a guideline or checklist with unweighted scoring methods, when evaluating health economic analyses.

These checklists are not limited to simply ascertaining whether the individual items have been addressed or not. Some of the checklists (e.g., Drummond and Jefferson, 1996^35^) require an assessment of the clarity and appropriateness with which the individual items have been tackled. Others (e.g., Sacristán, 1993^29^) used a scoring scale for each item with the following possibilities: 4 = correct, 3 = acceptable, 2 = doubtful, 1 = not reported, 0 = incorrect, NA = not applicable. It will often be difficult to choose between a “Yes” or “No” response. Some items regrouped various criteria. Consequently, if only one of the criteria in a group was not addressed, a “no” response should be given, even if the other criteria were addressed adequately. The possibility to use an intermediate value as “partially respected” could thus be interesting. This problem was mostly present with the QHES instrument. For example, one item tested if the time horizon was relevant, if costs and outcomes were discounted, and if the discount rate was justified. It would be interesting to test the impact of subdividing this kind of item.

## Reliability and Validity of the Checklists for Assessing the Quality of an Economic Evaluation

Clearly an accepted quality assessment tool could be a substantial contribution if it assists end users of cost-effectiveness studies to discriminate among the exploding body of literature and efficiently identify the studies with superior merit. For producers of such studies, an accepted checklist could establish a clearer standard, potentially encouraging higher quality and greater rigor. To achieve this level of acceptance and use, however, the checklist must have evidence of validity and reliability. Unfortunately, only some of the tools reviewed have been formally validated or shown to be reliable. One difficulty with assessing validity in this case is that there is no gold standard. Study findings with respect to reliability and inter-instrument comparisons were discussed above.

While Au38concluded that there is little improvement in reliability to be gained from using more than one rater or more than one assessment of quality, Gerken's37 study illustrated that the results of the quality assessment of economic evaluations were influenced more by the assessor than by the instrument used. These authors therefore concluded that quality assessments should be performed by at least two independent experts with final scoring based on consensus.

Beyond being reliable, the tools must rate studies on how well they actually answer the question posed by the research. The BMJ and QHES tools were assessed for concurrent validity by comparing them with each other (in addition to the Canadian guidelines,46 and the Journal of the American Medical Association user' guide47). The results of the Au et al. (2008) study suggested that the QHES and the Pediatrics Quality Appraisal Questionnaire (PQAQ) perform equally well. They concluded that the choice between them can therefore be based on other criteria; simplicity and speed of application in the case of one, and detail in the information provided in the case of the other. Both tools as well as the PQAQ and CHEC tools were also assessed against the opinion of experts (“criterion validity”) and validated among economists and some decisionmakers. However, we were concerned about potential bias in the methods for selecting these experts, as evidenced by the large representation from the pharmaceutical industry for the QHES tool, and the use of convenience sampling at an annual meeting of a professional society. Hence, the results may overestimate the utility of the instruments.

Acceptance of an instrument as scientifically sound requires that it represent the full content of each of the attributes being measured (“content validity”). While content validity may be relatively easy to assess in established disciplines and with established tests, content validity has proven to be exceedingly difficult to establish with evolving concepts or disciplines, such as cost-effectiveness analysis. The tools reviewed address many of the essential domains by which the soundness of an economic analysis is assessed; however, to the extent that it omits items pertinent to, for example, observational qualitative studies, their content validity might be compromised. Such studies may involve domains that are not captured by the questions in the tools.

The value of an applied instrument is largely determined by its construct validity, a concept more appropriate to a dynamic field such as cost-effectiveness analysis. Construct validity is established over time by the consistency of findings across different users. Such consistency was found by the experts consulted for the QHES study, and, to that extent, the instrument was determined to have adequate construct validity. However, results from its application have yet to be demonstrated across the spectrum of decisionmakers (e.g., health plans, managed care providers, pharmacy benefit managers, hospital pharmacy and therapeutics committees, or researchers), or for the range of the decisions that must be made.

## Systematic Reviews and Critical Appraisal

Given that only a few studies are relevant for any given topic, reviewers must set eligibility criteria to exclude low-quality analyses while still retaining enough studies, if possible, to evaluate important differences in model structure and inputs for key variables. Even when a checklist meets high standards, it may not identify studies that meet the need of a specific review. Decisions to include or exclude such studies should therefore be made on the basis of an overall judgment regarding their methodological quality, as well as their relevance in terms of the economic questions, interventions, populations, and outcomes being studied. This may require an iterative process; in this, analysts may set final selection criteria only after initially assessing the quantity and quality of the extant literature.22

Research is needed to examine which criteria for assessing the validity of cost-effectiveness studies are important determinants of study results and in what situations. For example, what is the relationship between quality scores (QHES, as an example) and treatment effect (i.e., cost-effectiveness measure)? Do lower scoring studies tend to produce more variable estimates of cost-effectiveness? Do certain components of the checklist (e.g., sufficient time horizon) relate to the size of the treatment effect? Do quality scores vary across study type (i.e., randomized controlled trial, model, and observational study)?

We did not find any reports of empirical research investigating the impact upon the results of a critical review of health economics studies of decisions to include economics studies that meet some but not all standards of methodological quality. However, as with the choice of eligibility criteria relating to quality and design of effectiveness studies, and to the design of health economics studies, it is plausible that use of different data sources for measures of resource use, cost and/or cost-effectiveness has the potential to impact on results.22