# Checklist Details

Table G-1 Checklist described in Adams, 1992^1^

Identification of comparison alternatives; 1. Did the authors provide a detailed description of the alternatives?; a. Yes, all of the alternatives; b. Some, but not all of the alternatives; c. No; 2. Were any important alternatives omitted?; a. Yes; b. No; Identification of costs and monetary savings; 3 How were direct costs measured?; a. Opportunity costs; b. Charges; c. Deflated charges (using cost-to-charge ratios); d. Market prices of resources consumed; e. Average cost (per patient day, etc.); f. No details provided; g. Other method(s) _______________________; h. No direct costs measured; 4 Were direct incremental costs and monetary savings measured correctly?; a. Yes, all were measured correctly; b. Some, but not all were measured correctly; c. No; d. Not measured; 5 How were overhead costs allocated?; a. Direct allocation; b. Step down allocation; c. Step down allocation with iteration; d. Simultaneous allocation; e. Other method_________________________; f. Not measured; 6 Were the overhead costs allocated appropriately?; a. Yes, all were allocated appropriately; b. Some, but not all were allocated appropriately; c. No; d. Appropriately not considered; e. Not measured; 7 Was the opportunity cost of capital measured correctly?; a. Yes; b. No; c. Not measured; d. Appropriately not considered; 8 Was depreciation considered appropriately and measured correctly?; a. Yes; b. No; c. Not measured; d. Appropriately not considered; 9 How were indirect costs measured?; a. Market valuation; b. Willingness to pay; c. Compensating variations; d. Equivalent variations; e. Other method(s)__________________________; f. Not measured; 10 Were indirect incremental costs and monetary savings measured correctly?; a. Yes, all were measured correctly; b. Some, but not all were measured correctly; c. No; d. Appropriately not measured; e. Not measured; 11 Were the incremental costs and monetary savings (direct and indirect) adjusted appropriately for differential timing (discounting, inflation and time-value of money)?; a. Yes, all were adjusted appropriately; b. Some, but not all were adjusted appropriately; c. No; d. Appropriately not measured; e. Not adjusted; 12 Was an appropriate sensitivity analysis conducted correctly?; a. Complete and correct analysis; b. Partial sensitivity analysis; c. No sensitivity analysis; Identification of benefits; 13 How were benefits measured?; a. Life years gained ( days, months); b. Quality-adjusted life years (days, months); c. Per positive screening/or correctly diagnosed case; d. Change in utilization; e. Market valuations; f. Opportunity costs; g. Compensating variations; h. Equivalent variations; i. Charges or deflated charges; j. Average cost per day (per diem); k. Other method(s) __________________________; l. Not stated; 14 Were direct incremental benefits measured correctly?; a. Yes, all were measured correctly; b. Some, but not all were measured correctly; c. No; d. Not measured; 15 Were indirect incremental benefits measured correctly?; a. Yes, all were measured correctly; b. Some, but not all were measured correctly; c. No; d. Appropriately not measured; e. Not measured; 16 Were the incremental benefits adjusted appropriately for differential timing?; a. Yes, all were adjusted appropriately; b. Some, but not all were adjusted appropriately; c. No; d. Appropriately not adjusted; e. Not adjusted; 17 Was an appropriate sensitivity analysis conducted correctly?; a. Complete and correct analysis?; b. Partial sensitivity analysis; c. No sensitivity analysis; Consideration of distributional effect; 18 Were the distributional effects of the study alternatives considered?; a. Yes, full discussion; b. Yes, partial discussion; c. No discussion; 19 Were the distributional effects analyzed appropriately?; a. Yes; b. No; c. Not analysed; Aggregation of valued costs and effects; 20 Were the incremental costs and benefits aggregated correctly?; a. Yes; b. Only partial; c. No; 21 Were the uncertainties regarding the cost and benefit estimates, the incidence of side effects, probabilities of being in different states of nature, and the clinical decision making process discussed?; a. Full discussion; b. Partial discussion; c. No discussion

Table G-2 Checklist described in Gerard, 1992^2^

Background characteristics; 1. Type of health care strategy; 2. Type of disease; 3. Type of health care intervention; 4. client group; 5. Country of study; 6. Academic Departments . Research Centres; 7. Person(s) most responsible for evaluation/studies with/without a health economics input; 8. Funding agency; Technical criteria; 9 Objectives of study^*^; 10 Type and adequacy of comparisons^*^; Costs; 11 Cost perspective; 12 Cost coverage; 13 Cost comprehensiveness^*^; 14 Clarity of cost measurement; 15 Type of cost measurement; 16 Source and description of cost valuation; 17 Clarity of the price base used; Outcome; 18 Outcome coverage^*^; 19 Type of outcome coverage; 20 Clarity and type of added life measurement; 21 Type of quality of life measurement; 22 Quality of life measurement techniques; 23 Source of QALY valuations; 24 Clarity of assignment of valuation in health states; 25 Discounting; 26 Sensitivity analysis^*^; 27 Source/type of effectiveness evidence; 28 timing of CUA with effectiveness evidence; 29 Stage of technical development of intervention; Policy relevance criteria; 30 Additional value of CUA vis-à-vis CEA; 31 Results brought to policy-makers' attention; 32 Generalise results to other settings; 33 Use and construction of QALY league tables; General quality of studies; 34 Sensible objectives; 35 Main potential value; 36 Execution; 37 General (or overall) assessment

* denotes key technical criteria used in the overall assessment of the quality of the study. This assessment of overall technical quality is applied only to studies judged worthwhile because objectives were sensible and the CUA approach was appropriate.

Table G-3 Checklist described by Sacristan, 1993^3^

1. Definition of study aim; Does a well defined question exist?; Are the perspectives and alternatives compared clearly specified?; 2. Sample selection; Are the types of patients chosen suitable and are they specified?; Are the diagnostic criteria adequately specified?; 3. Analysis of alternatives; Are all the relevant alternatives analyzed?; Are the comparison alternatives suitable?; Is this the most commonly used treatment?; Is the indication the most relevant one?; Are adequate dosages used?; Are the treatments reproducible? (doses, interval, duration, etc.); Is the ‘do nothing’ option suitable or should it be analyzed?; Is a decision analysis applied?; 4. Analysis of perspective; Is it clearly specified (society, patient, hospital, etc.)?; Is it justified for the question asked?; 5. Measurement of benefits; Is it adequate for the question asked and the perspective?; Are the data on the effectiveness of alternatives adequately established?; Is the main assessment variable, objective and relevant?; Is the time fixed for the evaluation sufficient and is it specified?; Are the results quantified by time?; 6. Measurement of costs; Is the measurement of costs suitable for the perspective; Are the costs up to date and the prices those of the market?; Is an adjustment of future costs and benefits performed?; 7. Is the type of analysis used suitable?; Financial terms: cost-benefit; “Physical “units: cost-effectiveness; Quality of life/utility: cost-utility; Equal benefits: cost-minimization; 8. Analysis of the results; If intermediate variables are used, are they representative of the end benefit?; Is a marginal analysis performed?; Are the costs and consequences of adverse affects analyzed?; 9. Is the evaluation suitable if carried out within a clinical trial?; Is the suitable methodology employed?; Are the statistical methods used adequate?; Is an analysis according to ‘intention to treat” made?; Are costs resulting from the trial, which differ from those in normal practice, taken into account?; 10. Are the assumptions and the limitations of the study discussed?; Is a sensitivity analysis performed?; Do the assumptions have a basis?; Is the exclusion of any important variable analyzed or justified?; If intermediate endpoints are assumed, are limitations discussed?; 11. Are the possible ethical problems discussed and identified?; 12. Conclusions; Are they justified?; Can they be generalized? Can they be extrapolated to daily clinical practice?

Table G-4 Checklist described in Clemens, 1995^4^

Research design; 1. Individual researchers should be free to choose from multiple research design and data source options that have been described in the literature.; Protocol/report; 2 Study objectives and rationale for the outcome measures, data sources and analysis methods chosen should be stated in a research proposal or protocol.; 3 A final report should be available that describes all assumptions, methods and data sources in sufficient detail that readers can reproduce the key results.; Contents of protocol/report; 4 The study should clearly specify the target population or patient subgroups.; 5 Alternative treatments such as other drugs, surgical intervention or ‘do nothing’ should be stated in the study design including a discussion of their costs, frequency of use and relevance for the population of interest.; 6 Time horizons for the analysis should be stated and should be based on the likely use and effect of the drug, together with the weight and strength of data availability.; 7 The study should clearly define the type of analyses and rationale for their use.; 8 Uncertainty should be demonstrated by: (i) statistical analysis to address random events; and (ii) sensitivity analysis to cover a range of assumptions.; Costs/resources; 9 The perspective of the analysis (societal, third-party payer, etc) and clear reasons for its selection should be stated.; 10 Resources should be relevant to the perspective and described in natural units before a cost analysis is performed.; 11 Categories of costs (direct medical, direct nonmedical and indirect) should be identified and presented separately.; 12 Resources/costs should be presented as increments (difference between alternatives) as well as totals.; 13 Costs should be discounted for analyses with time horizons greater than 1 year.; 14 The source(s) and methods of deriving the costs/charges should be clearly stated and validated.; Effectiveness/benefits; 15 Consequences being evaluated (monetary benefit, effectiveness, quality of life, utility, efficacy, safety, morbidity, mortality) and their sources should be clearly stated.; 16 Effectiveness/benefit measures should be discounted, when appropriate, for analyses with time horizons of greater than 1 year.; 17 Effectiveness/benefit measures should be presented as increments (difference between alternatives) as well as totals.; Data sources; 18 Methods for the estimation of quantities and unit costs are described.; 19 The quality of the database should be documented (e.g., methods of data assembly, limitations such as missing data, validation methods).; 20 Expert clinical opinion may be used for certain limited purposes when other data sources are not available (e.g., dealing with missing data, adjusting for protocol-driven resource usage, estimating probabilities in decision analysis, and when collection of primary data is unethical).; Extrapolation of results to other settings Effectiveness and resource data from one setting may be extrapolated to other settings if differences in medical intervention, treatment patterns, outcomes of existing treatment, and populations are addressed.

Table G-5 Checklist described by the US Panel, 1996^5-7^

Framework; 1. Background of the problem; 2. General framing and design of the analysis; 3. Target population for intervention; 4. Other program descriptors (eg, care setting, model of delivery, timing of intervention); 5. Description of comparator programs; 6. Boundaries of the analysis; 7. Time horizon; 8. Statement of the perspective of the analysis; Data and Methods; 9 Description of event pathway; 10 Identification of outcomes of interest in analysis; 11 Description of model used; 12 Modeling assumptions; 13 Diagram of event pathway; 14 Software used; 15 Complete description of estimates of effectiveness, resource use, unit costs, health states, and quality of life weights and their sources; 16 Methods for obtaining estimates of effectiveness, costs and preferences; 17 Critique of data quality; 18 Statement of year of costs; 19 Statement of method used to adjust costs for inflation; 20 Statement of type of currency; 21 Source and methods for obtaining expert judgment; 22 Statement of discount rates; Results; 23 Results of model validation; 24 Reference case results (discounted at 3% and undiscounted): total costs and effectiveness, incremental costs and effectiveness, and incremental cost effectiveness ratios; 25 Results of sensitivity analyses; 26 Other estimates of uncertainty, if available; 27 Aggregate cost and effectiveness information; 28 Disaggregated results, as relevant; 29 Secondary analyses using 5% discount rate; 30 Other secondary analyses, as relevant; Discussion; 31 Summary of reference case results; 32 Summary of sensitivity of results to assumptions and uncertainties in the analysis; 33 Discussion of analysis assumptions having important ethical implications; 34 Limitations of the study; 35 Relevance of study results for specific policy questions or decisions; 36 Results of related cost-effectiveness analyses; 37 Distributive implications of an intervention

Table G-6 The Paediatric Quality Appraisal Questionnaire Described by Ungar, 2003^8^

Economic Evaluation; 1. Is the research question posed in terms of costs and consequences?; 2. Is a specific type of economic analysis technique performed?; 3. What type of analytic technique is performed, according to the authors?; Comparators; 4 Is there a rationale for choosing the intervention(s) being investigated?; 5 Is there a rationale for choosing the alternative program(s) or intervention(s) used for comparison?; 6 Does the report describe the alternatives in adequate detail?; 7 Is a description of the event pathway provided?; 8 Is a formal decision analysis performed?; Target Population; 9 Is the target population for the intervention identified?; 10 Are the subjects representative of the population to which the intervention is targeted?; Time Horizon; 11 Is there a time horizon for both costs and outcomes?; 12 Do the authors justify the time horizon selected?; Perspective; 13 Is a perspective for the analysis given?; 14 Is a societal perspective taken, either alone or in addition to other perspectives?; 15 When there is more than one perspective, are the results of each perspective presented separately?; Costs and Resource Use; 16 Are all relevant costs for each alternative included?; 17 Are opportunity costs of lost time (productivity costs) for parents and informal caregivers measured when required?; 18 Do cost item identification and valuation extend beyond the health-care system to include school and community resources when necessary?; 19 Are future salary and productivity changes of the child taken into consideration when appropriate?; 20 Are all of the sources for estimating the volume of resource use described?; 21 Are all the sources for estimating all of the unit costs described?; Outcomes; 22 Is a primary health outcome given?; 23 Do the authors justify the health outcome(s) selected?; 24 Is effectiveness, rather than efficacy, assessed?; 25 What approach is used to assess the effectiveness/efficacy?; 26 Are the details of the design of the effectiveness/efficacy study(s) provided?; 27 Are the results of the efficacy/effectiveness of alternatives reported?; 28 Are school/day-care absences taken into consideration?; 29 if intermediate outcome variables are used, are they linked by evidence or reference to the end benefit?; Quality of Life; 30 If quality of life is measured, what type of instrument is used?; 31 Whose quality of life is assessed?; 32 Who performed the quality-of-life assessment?; Analysis; 33 Are costs AND outcomes measured in units appropriate for the indicated analytic technique?; 34 For prospective studies that use interviews, questionnaires, or surveys, how are data obtained in studies involving young children?; 35 How are direct costs valued?; 36 How are productivity costs valued?; 37 Are costs valued appropriately?; 38 Is the valuation of outcomes appropriate for the type of analysis?; 39 What is the unit of analysis used for expressing the final results?; 40 Are quantities of resources used reported separately from their unit costs?; 41 Are the costs aggregated correctly?; 42 Are details of statistical tests and confidence intervals given for stochastic data?; Discounting; 43 When required, are costs and consequences that occur over more than 1 year discounted to their present values?; 44 If costs or benefits are not discounted when the time horizon exceeds 1 year, is an explanation provided?; Incremental Analysis; 45 Are incremental estimates of costs and outcomes presented?; 46 Are the incremental estimates summarized as incremental ratios?; 47 Are confidence intervals/limits calculated for incremental ratios or incremental estimates of costs and outcomes?; Sensitivity Analysis; 48 Are all important assumptions given?; 49 Is a sensitivity analysis performed?; 50 Do the authors justify the alternative values or ranges for sensitivity analysis?; 51 What methods are used to assess uncertainty?; Conflict of Interest; 52 Does the article present the relationship with the sponsor of the study?; 53 Does the article indicate that the authors had independent control over the methods and right to publish?; Conclusions; 54 Is the answer to the study question provided?; 55 Are the most important limitations of the study discussed?; 56 Do the authors generalize the conclusions to other settings or patient/client groups?; 57 Global impression of the quality of the article.

Table G-7 The British Medical Journal Checklist described by Drummond, 1996^9^

Study design; 1. The research question is stated; 2. The economic importance of the research question is stated; 3. The viewpoints of the analysis are clearly stated and justified; 4. The rationale for choosing the alternative programmes or interventions compared is stated; 5. The alternatives being compared are clearly described; 6. The form of economic evaluation used is stated; 7. The choice of form of economic evaluation is justified in relation to the questions addressed; Data collection; 8 The sources of effectiveness estimates used are stated; 9 Details of the design and results of effectiveness study are given (if based on a single study); 10 Details of the method of synthesis or meta-analysis of estimates are given (if based on an overview of a number of effectiveness studies); 11 The primary outcome measure(s) for the economic evaluation are clearly stated; 12 Methods to value health states and other benefits are stated; 13 Details of the subjects from whom evaluations were obtained are given; 14 Productivity changes (if included) are reported separately; 15 The relevance of productivity changes to the study question is discussed; 16 Quantities of resources are reported separately from their unit costs; 17 Methods for the estimation of quantities and unit costs are described; 18 Currency and price data are recorded; 19 Details of currency or price adjustments for inflation or currency conversion are given; 20 Details of any model used are given; 21 The choice of model used and the key parameters on which it is based are justified; Analysis and interpretation of results; 22 Time horizon of costs and benefits is stated; 23 The discount rate(s) is stated; 24 The choice of rate(s) is justified; 25 An explanation is given if costs or benefits are not discounted; 26 Details of statistical tests and confidence intervals are given for stochastic data; 27 The approach to sensitivity analysis is given; 28 The choice of variables for sensitivity analysis is justified; 29 The ranges over which the variables are varied are stated; 30 Relevant alternatives are compared; 31 Incremental analysis is reported; 32 Major outcomes are presented in a disaggregated as well as aggregated form; 33 The answer to the study question is given; 34 Conclusion follow from the data reported Conclusions are accompanied by the appropriate caveats

Table G-8 The Quality of Health Economic Studies Instrument described by Chiou, 2003^10^

Item | | Weightings
1. | Was the study objective presented in a clear, specific, and measurable manner? | 7
2. | Were the perspective of the analysis (societal, third-party payer, and so on) and reasons for its selection stated? | 4
3. | Were variable estimates used in the analysis from the best available source (i.e., Randomized Control Trial-Best, Expert Opinion-Worst)? | 8
4. | If estimates came from a subgroup analysis, were the groups pre-specified at the beginning of the study? | 1
5. | Was uncertainty handled by: (i) statistical analysis to address random events; (ii) sensitivity analysis to cover a range of assumptions? | 9
6. | Was incremental analysis performed between alternatives for resources and costs? | 6
7. | Was the methodology for data abstraction (including value health states and other benefits) stated? | 5
8. | Did the analytic horizon allow time for all relevant and important outcomes? Were benefits and costs that went beyond 1 year discounted (3–5%) and justification given for the discount rate? | 7
9. | Was the measurement of costs appropriate and the methodology for the estimation of quantities and unit costs clearly described? | 8
10. | Was the primary outcome measure(s) for the economic evaluation clearly stated and were the major short term, long term and negative outcomes included? | 6
11. | Were the health outcomes measures/scales valid and reliable? If previously tested valid and reliable measures were not available, was justification given for the measures/scales used? | 7
12. | Were the economic model (including structure), study methods and analysis, and the components of the numerator and denominator displayed in a clear transparent manner? | 8
13. | Were the choice of economic model, main assumptions and limitations of the study stated and justified? | 7
14. | Did the author(s) explicitly discuss direction and magnitude of potential biases? | 6
15. | Were the conclusions/recommendations of the study justified and based on the study results? | 8
16. | Was there a statement disclosing the source of funding for the study? | 3

Table G-9 The Consensus Health Economic Criteria List described by Evers, 2005^11^

1. Is the study population clearly described?; 2. Are competing alternatives clearly described?; 3. Is a well-defined research question posed in answerable form?; 4. Is the economic study design appropriate to the stated objective?; 5. Is the chosen time horizon appropriate in order to include relevant costs and consequences?; 6. Is the actual perspective chosen appropriate?; 7. Are all important and relevant costs for each alternative identified?; 8. Are all costs measured appropriately in physical units?; 9. Are costs valued appropriately?; 10. Are all important and relevant outcomes for each alternative identified?; 11. Are all outcomes measured appropriately?; 12. Are outcomes valued appropriately?; 13. Is an incremental analysis of costs and outcomes of alternatives performed?; 14. Are all future costs and outcomes discounted appropriately?; 15. Are all important variables, whose values are uncertain, appropriately subjected to sensitivity analysis?; 16. Do the conclusions follow from the data reported?; 17. Does the study discuss the generalizability of the results to other settings and patient/client groups?; 18. Does the article indicate that there is no potential conflict of interest of study researcher(s) and funder(s)?; 19. Are ethical and distributional issues discussed appropriately?

Table G-10 Checklist to Frame Health Technology Assessments, Grutters, 2011^12^

1. | Objective How will the Health Technology Assessment be used?
2. | Audience What is the audience (principal users) for the HTA?
3. | Perspective Which viewpoint or perspective is relevant for the HTA?
4. | Population What is the patient population relevant for the decision problem?
5. | Comparators What are relevant comparators for the decision problem?
6. | Clinical Practice How are the technologies embedded in clinical practice?
7. | Time horizon Which time horizon is relevant for the decision problem?
8. | Consequences Which consequences are relevant for the decision problem?
9. | Patient Use What is the patient use that is relevant for the decision problem?
10. | Professional Use What is the use of the technology by health care professionals that is relevant for the problem?
11. | Price and Resource Use What price level and resource use are relevant for the decision problem?

## References

1 Adams ME, McCall NT, Gray DT, Orza MJ, Chalmers TC. Economic analysis in randomized control trials. Med Care. 1992;30(3):231-43. [pmid: 1538611].
2 Gerard K. Cost-utility in practice: a policy maker's guide to the state of the art. Health Policy. 1992;21(3):249-79. [pmid: 10120196].
3 Sacristan JA, Soto J, Galende I. Evaluation of pharmacoeconomic studies: utilization of a checklist. Ann Pharmacother. 1993;27(9):1126-33. [pmid: 8219449].
4 Clemens K, Townsend R, Luscombe F, Mauskopf J, Osterhaus J, Bobula J. Methodological and conduct principles for pharmacoeconomic research. Pharmaceutical Research and Manufacturers of America. Pharmacoeconomics. 1995;8(2):169-74. [pmid: 10155611].
5 Siegel JE, Weinstein MC, Russell LB, Gold MR. Recommendations for reporting cost-effectiveness analyses. Panel on Cost-Effectiveness in Health and Medicine. JAMA. 1996;276(16):1339-41. [pmid: 8861994].
6 Weinstein MC, Siegel JE, Gold MR, Kamlet MS, Russell LB. Recommendations of the Panel on Cost-effectiveness in Health and Medicine. JAMA. 1996;276(15):1253-8. [pmid: 8849754].
7 Russell LB, Gold MR, Siegel JE, Daniels N, Weinstein MC. The role of cost-effectiveness analysis in health and medicine. Panel on Cost-Effectiveness in Health and Medicine. JAMA. 1996;276(14):1172-7. [pmid: 8827972].
8 Ungar WJ, Santos MT. The Pediatric Quality Appraisal Questionnaire: an instrument for evaluation of the pediatric health economics literature. Value Health. 2003;6(5):584-94. [pmid: 14627065].
9 Drummond MF, Jefferson TO. Guidelines for authors and peer reviewers of economic submissions to the BMJ. The BMJ Economic Evaluation Working Party. BMJ. 1996;313(7052):275-83. [pmid: 8704542].
10 Chiou CF, Hay JW, Wallace JF, et al. Development and validation of a grading system for the quality of cost-effectiveness studies. Med Care. 2003;41(1):32-44. [pmid: 12544542].
11 Evers S, Goossens M, de Vet H, van Tulder M, Ament A. Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care. 2005;21(2):240-5. [pmid: 15921065].
12 Grutters JP, Seferina SC, Tjan-Heijnen VC, van Kampen RJ, Goettsch WG, Joore MA. Bridging trial and decision: a checklist to frame health technology assessments for resource allocation decisions. Value Health. 2011;14(5):777-84. [pmid: 21839418].