# Definition of Terms

Guidelines give instructions on how to adequately perform or report a study. A researcher performing an economic evaluation may use guidelines in designing and conducting a study.

A checklist is used after the study has been performed and after the results have been published to see if the study met specific guidelines. Of course, there will be a large overlap between guidelines and checklists for the same type of studies.

Criteria lists are used in systematic reviews to consider the methodological quality of the studies included. The criteria usually relate to the internal validity of the studies, but in some criteria lists external validity items are also included. Again, there may be some overlap between criteria lists and guidelines or checklists in a specific research field, but criteria lists are usually more compact and serve a different purpose. That is, the methodological quality assessed by a criteria list should indicate how high or low the chance is that the results of the study are inaccurate or misleading