# Results

## Key Question (KQ) 1 Bayesian Mixed Treatment Comparison (MTC) Methods Compared With Frequentist Indirect Methods, and Performance for Different Types of Evidence Network Patterns

We organized this section in two main parts: (1) comparison of results of Bayesian mixed treatment comparison (MTC) methods with those of various frequentist methods for the full evidence networks and (2) comparison of and performance for different types of evidence network patterns. For the second part, we divided the results into two subsections—one comparing results of Bayesian MTC methods with those of various frequentist methods for subcomponents (i.e., evidence network patterns) of the full networks and one presenting results of Bayesian MTC methods for the full networks and those of Bayesian MTC methods for subcomponents of the full networks. Within each part, we first address results using data from our second-generation antidepressants (SGAs) report and then results using data from our report on treatments for rheumatoid arthritis (RA).

### Comparison of Bayesian MTC Results With Those of Various Frequentist Analyses for the Full Networks

In this section, we provide results of comparisons between Bayesian MTC methods and three frequentist methods for the full networks illustrated in Appendix C. Tables in Appendix D provide detailed results for each analysis. Tables in Appendix E provide a comparison of precision of findings from the various analyses (determined by width of the 95% credible interval or confidence interval), with the darkest shading indicating the most precise result and the lightest indicating the least precise for each drug-drug comparison. The tables in this section provide a summary and some comparison of the data in Appendix D and Appendix E.

### Second-Generation Antidepressants: Response (Binary Outcome)

Appendix Table D-1 provides results of our analyses for the full SGA network for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, the Bucher method, and frequentist logistic regression (Appendix D). For 15 out of 78 drug-drug comparisons, neither frequentist meta-regression nor the Bucher method produced a result, either because no studies included a common comparator or because an insufficient number of studies included a common comparator for the program to run the analysis.

Table 3 summarizes the number of comparisons for which each frequentist method was unable to produce a result (the Bayesian MTC method produced results for all 78 comparisons), the percent agreement and kappa between each frequentist method and the Bayesian MTC method, and comparative precision. The three frequentist methods were unable to produce a result for 0 percent (0/78), 32 percent (25/78), and 45 percent (35/75) of the drug-drug comparisons (for the logistic regression, meta-regression, and Bucher methods, respectively). Logistic regression always produced the most precise result and Bayesian MTC was the next most precise for all but one drug-drug comparison (Appendix Table E-1).

Table 3 Comparison of findings for SGA response between Bayesian MTC meta-analysis findings and those of frequentist methods: agreement and kappas

Outcome | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
No result produced^a^ | 0 of 78 comparisons | 25 of 78 comparisons | 35 of 78 comparisons | 0 of 78 comparisons
% agreement with Bayesian MTC^b^ | NA | 94.3 (50/53) | 93.0 (40/43) | 100
Kappa^c^ | NA | NA | NA | 1.00
Precision | 2^nd^ most precise | Least precise | 3^rd^ most precise | Most precise

MTC = mixed treatment comparison; NA = not applicable; SGA = second-generation antidepressant

a No result produced indicated the number of drug-drug comparisons for which the method was unable to produce a result, either because no studies had a common comparator or an insufficient number of studies had a common comparator.

b Percent agreement calculated only for drug-drug comparisons that both methods were able to produce a result. For example, meta-regression did not produce a result for 25 of 78 drug-drug comparisons. Therefore, the percent agreement was calculated using the 53 comparisons for which both methods produced a result. Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

c Kappa was calculated only for comparisons when both methods were able to produce a result, as with percent agreement. Not applicable (NA) indicates that the statistical program was unable to calculate a kappa because of insufficient data.

For the results of the three drug-drug comparisons that were not in agreement between the Bayesian MTC and the meta-regression and Bucher methods (duloxetine vs. escitalopram, escitalopram vs. fluoxetine, and fluoxetine vs. venlafaxine), the Bayesian MTC meta-analysis found a potentially important difference (based on 95% credible intervals) between treatments, whereas the other two methods did not. In addition, the results of the Bayesian MTC had greater precision than the other two methods for all three comparisons. Point estimates were very similar for the three methods for one of the comparisons (fluoxetine vs. venlafaxine, odds rations [ORs] ranged from 0.75 to 0.77) but not for the other two comparisons (duloxetine vs. escitalopram: ORs 0.74 vs. 1.23 vs. 1.19, respectively; escitalopram vs. fluoxetine: ORs 1.44 vs. 0.94 vs. 0.94).

### Second-Generation Antidepressants: Mean Change in HAM-D (Continuous Outcome)

Appendix Table D-2 provides results of our analyses for the full SGA network for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, and the Bucher method (Appendix D). There are no results from frequentist logistic regression for this outcome because it is a continuous outcome.

For 33 out of 78 drug-drug comparisons, neither of the frequentist methods produced a result either because no studies included a common comparator or because an insufficient number of studies included a common comparator for the program to run the analysis. Table 4 summarizes the number of comparisons for which each frequentist method was unable to produce a result (the Bayesian MTC method produced results for all 78 comparisons) as well as the percent agreement between each frequentist method and the Bayesian MTC method. Bayesian MTC meta-analysis produced the most precise result for 67 percent of the comparisons; the Bucher method was the most precise for 33 percent of the comparisons (Appendix Table E-2).

Table 4 Comparison of findings for mean change in HAM-D between Bayesian MTC meta-analysis findings and those of frequentist methods: agreement and kappas

Outcome | Bayesian MTC | Meta-Regression | Bucher Method
No result produced^a^ | 0 of 78 comparisons | 46 of 78 comparisons | 33 of 78 comparisons
% agreement with Bayesian MTC^b^ | NA | 100 (32/32) | 84.4 (38/45)
Kappa^c^ | NA | NA | NA
Precision | Most precise | Least precise | 2^nd^ most precise

HAM-D = Hamilton Depression rating scale; MTC = mixed treatment comparison; NA = not applicable

a No result produced indicated the number of drug-drug comparisons for which the method was unable to produce a result, either because no studies had a common comparator or an insufficient number of studies had a common comparator.

b Percent agreement calculated only for drug-drug comparisons that both methods were able to produce a result. Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

c Not applicable (NA) indicates that the statistical program was unable to calculate a kappa because of insufficient data.

For the results of the seven drug-drug comparisons that were not in agreement between the Bayesian MTC and the Bucher methods, the Bucher method found a statistically significant difference between treatments, whereas the Bayesian MTC method did not find an important difference (based on the 95% credible interval). The seven comparisons were duloxetine versus mirtazapine, duloxetine versus venlafaxine, escitalopram versus trazodone, escitalopram versus venlafaxine, mirtazapine versus venlafaxine, paroxetine versus venlafaxine, and sertraline versus venlafaxine. The Bayesian MTC method usually produced a more precise result (based on comparison of credible intervals with confidence intervals), but the point estimates differed in magnitude and sometimes in the direction (three of the seven) of effect (i.e., point estimates trended in opposite directions, favoring different treatments).

### Biologic Disease-Modifying Antirheumatic Drugs for Rheumatoid Arthritis: ACR 50 (Binary Outcome)

Appendix Table D-3 provides results of our analyses for the full biologic DMARDs network for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, the Bucher method, and frequentist logistic regression (Appendix D). For all 28 drug-drug comparisons, all four methods were able to produce results. Table 5 summarizes the percent agreement and kappa between each frequentist method and the Bayesian MTC method. Logistic regression produced the most precise result for 89 percent of the comparisons; the Bayesian MTC meta-analysis produced the third most precise result for 86 percent of the comparisons (Appendix Table E-3).

Table 5 Comparison of findings for ACR 50 between Bayesian MTC meta-analysis findings and those of frequentist methods: agreement and kappas

Outcome | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
No result produced | 0 of 28 comparisons | 0 of 28 comparisons | 0 of 28 comparisons | 0 of 28 comparisons
% agreement with Bayesian MTC^a^ | NA | 96.4 (27/28) | 92.9 (26/28) | 82.1 (23/28)
Kappa | NA | 0.90 | 0.83 | 0.62
Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise

ACR 50 = American College of Rheumatology 50 percent response; MT C= mixed treatment comparison; NA = not applicable

a Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

For the results of the one drug-drug comparison (adalimumab vs. anakinra) that was not in agreement between the Bayesian MTC meta-analysis and meta-regression, the Bayesian MTC method found a potentially important result favoring adalimumab over anakinra (OR, 1.88, 95% CrI 1.01 to 3.98). Meta-regression found a similar point estimate but with a wider confidence interval not reaching statistical significance (OR, 1.95, 95%, CI, 0.82 to 4.61).

For the results of both drug-drug comparisons (anakinra vs. golimumab and etanercept vs. golimumab) that were not in agreement between the Bayesian MTC and the Bucher method, the Bucher method found a statistically significant difference between treatments, whereas the Bayesian MTC did not find an important difference. Point estimates for both were fairly similar and in the same direction, but the confidence intervals were more narrow (reaching statistical significance) for the Bucher method.

For the results of the five drug-drug comparisons that were not in agreement between the Bayesian MTC and logistic regression, logistic regression found a statistically significant difference between treatments, whereas the Bayesian MTC did not find an important difference. The five comparisons were abatacept versus anakinra, anakinra versus golimumab, anakinra versus infliximab, anakinra versus rituximab, and anakinra versus tocilizumab. Point estimates were fairly similar and were in the same direction for all five for the Bayesian MTC meta-analysis and logistic regression, but the confidence intervals were more narrow (reaching statistical significance) for logistic regression.

### Performance for Different Types of Evidence Network Patterns

#### Comparison of Bayesian MTC Results With Those of Various Frequentist Analyses for Subcomponents of the Full Networks

In this section, we provide results of comparisons between Bayesian MTC methods and three frequentist methods for the subcomponents of the full networks illustrated in Appendix C. These subcomponents represent at least one of each of the following network patterns: placebo star, loop, one closed loop, and ladder. Tables in Appendix D provide detailed results for each analysis by network pattern. Tables in Appendix E provide a comparison of precision of findings from the various analyses (determined by width of the 95% credible interval or confidence interval), with the darkest shading indicating the most precise result and the lightest indicating the least precise for each drug-drug comparison. The tables in this section provide a summary and some comparison of the data in Appendix D and Appendix E.

#### Second-Generation Antidepressants: Response (Binary Outcome)

Appendix Tables D-4 through D-7 provide results of our analyses for each of the network patterns (sub-components of the full network) selected, including a placebo star, loop, one closed loop, and ladder for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, the Bucher method, and frequentist logistic regression (Appendix D). Table 6 summarizes the number of comparisons for which each frequentist method was unable to produce a result as well as the percent agreement and kappa between each frequentist method and the Bayesian MTC method by network pattern. On average, logistic regression produced the most precise results for the star, one closed loop, and ladder, whereas the Bayesian MTC meta-analysis produced the most precise results for the loop (Appendix Tables E-4 through E-7).

Table 6 Comparison of findings for SGA response between Bayesian MTC meta-analysis findings and those of frequentist methods for various network patterns

Network Pattern | Outcome | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
Star | No result produced^a^ | 0 of 45 comparisons | 3 of 45 comparisons | 2 of 45 comparisons | 0 of 45 comparisons
Star | % agreement with Bayesian MTC^b^ | NA | 100 | 100 | 100
Star | Kappa^c^ | NA | NA | NA | NA
Star | Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise
Loop | No result produced^a^ | 0 of 3 | 0 of 3 | 0 of 3 | 0 of 3
Loop | % agreement with Bayesian MTC^b^ | NA | 66.7 (2/3) | 66.7 (2/3) | 66.7 (2/3)
Loop | Kappa^c^ | NA | NA | NA | NA
Loop | Precision | Most precise | Least precise | 3^rd^ most precise | 2^nd^ most precise
One closed loop | No result produced^a^ | 0 of 32 | 25 of 32 | 25 of 32 | 0 of 32
One closed loop | % agreement with Bayesian MTC^b^ | NA | 85.7 | 85.7 | 93.8
One closed loop | Kappa^c^ | NA | NA | NA | 0.6364
One closed loop | Precision | 2^nd^ most precise | Least precise | 3^rd^ most precise | Most precise
Ladder | No result produced^a^ | 0 of 55 | 39 of 55 | 36 of 55 | 0 of 55
Ladder | % agreement with Bayesian MTC^b^ | NA | 100 | 100 | 96.4
Ladder | Kappa^c^ | NA | NA | NA | 0.6474
Ladder | Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise

MTC = mixed treatment comparison; NA = not applicable; SGA = second-generation antidepressant

a No result produced indicated the number of drug-drug comparisons for which the method was unable to produce a result, either because no studies had a common comparator or an insufficient number of studies had a common comparator.

b Percent agreement calculated only for drug-drug comparisons that both methods were able to produce a result. Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

c Kappa was calculated only for comparisons when both methods were able to produce a result, as with percent agreement. Not applicable (NA) indicates that the statistical program was unable to calculate a kappa because of insufficient data (because there were fewer than two levels).

#### Second-Generation Antidepressants: Mean Change in HAM-D (Continuous Outcome)

Appendix Tables D-8 through D-11 provide results of our analyses for each of the network patterns (sub-components of the full network) selected, including a placebo star, loop, one closed loop, and ladder for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, and the Bucher method (Appendix D). There are no results from frequentist logistic regression for this outcome because it is a continuous outcome.

Table 7 summarizes the number of comparisons for which each frequentist method was unable to produce a result (the Bayesian MTC method produced results for all comparisons) as well as the percent agreement and kappa between each frequentist method and the Bayesian MTC method, by network pattern. For the one closed loop and ladder patterns, the frequentist methods did not produce a result for the majority of drug-drug comparisons. On average, logistic regression produced the most precise results for the star and ladder, the Bayesian MTC meta-analysis produced the most precise results for the loop, and meta-regression produced the least precise results for all network patterns (Appendix Tables E-8 through E-11).

Table 7 Comparison of findings for mean change in HAM-D between Bayesian MTC meta-analysis findings and those of frequentist methods for various network patterns

Network Pattern | Outcome | Bayesian MTC | Meta-Regression | Bucher Method
Star | No result produced^a^ | 0 of 21 comparisons | 1 of 21 comparisons | 0 of 21 comparisons
Star | % agreement with Bayesian MTC^b^ | NA | 100 (20/20) | 81 (17/21)
Star | Kappa^c^ | NA | NA | NA
Star | Precision | 2^nd^ most precise | Least precise | Most precise
Loop | No result produced^a^ | 0 of 3 comparisons | 2 of 3 comparisons | 0 of 3 comparisons
Loop | % agreement with Bayesian MTC^b^ | NA | 100 (1/1) | 100 (3/3)
Loop | Kappa^c^ | NA | NA | NA
Loop | Precision | Most precise | Least precise | 2^nd^ most precise
One closed loop | No result produced^a^ | 0 of 21 comparisons | 17 of 21 comparisons | 14 of 21 comparisons
One closed loop | % agreement with Bayesian MTC^b^ | NA | 100 (4/4) | 85.7 (6/7)
One closed loop | Kappa^c^ | NA | NA | NA
One closed loop | Precision | Most precise^d^ | Least precise | Most precise^d^
Ladder | No result produced^a^ | 0 of 28 comparisons | 25 of 28 comparisons | 23 of 28 comparisons
Ladder | % agreement with Bayesian MTC^b^ | NA | 100 (3/3) | 100 (5/5)
Ladder | Kappa^c^ | NA | NA | NA
Ladder | Precision | 2^nd^ most precise | Least precise | Most precise

HAM-D = Hamilton Depression rating scale; MTC = mixed treatment comparison; NA = not applicable

a No result produced indicated the number of drug-drug comparisons for which the method was unable to produce a result, either because no studies had a common comparator or an insufficient number of studies had a common comparator.

b Percent agreement calculated only for drug-drug comparisons that both methods were able to produce a result. Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

c Kappa was calculated only for comparisons when both methods were able to produce a result. Not applicable (NA) indicates that the statistical program was unable to calculate a kappa because of insufficient data (because there were fewer than two levels).

d Neither the Bayesian MTC method nor the Bucher method was clearly more precise than the other. Each of them reported the most precise results for about half of the drug-drug comparisons.

#### Biologic Disease-Modifying Antirheumatic Drugs for Rheumatoid Arthritis: ACR 50 (Binary Outcome)

Appendix Tables D-12 through D-16 provide results of our analyses for each of the network patterns (subcomponents of the full network) selected, including a placebo star, loop, one closed loop, and ladder for each drug-drug comparison for Bayesian MTC meta-analyses, frequentist meta-regression, the Bucher method, and frequentist logistic regression (Appendix D). Table 8 summarizes the number of comparisons for which each method was unable to produce a result, as well as the percent agreement and kappa between each frequentist method and the Bayesian MTC method by network pattern. On average, logistic regression produced the most precise results for all of the network patterns; the Bayesian MTC meta-analysis produced the third most precise or the least precise results, depending on the network pattern (Appendix Tables E-12 through E-16).

Table 8 Comparison of findings for ACR 50 response between Bayesian MTC meta-analysis findings and those of frequentist methods for various network patterns

Network Pattern | Outcome | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
Star | No result produced^a^ | 0 of 28 comparisons | 0 of 28 comparisons | 0 of 28 comparisons | 0 of 28 comparisons
Star | % agreement with Bayesian MTC^b^ | NA | 100 (28/28) | 89.3 (25/28) | 78.6 (22/28)
Star | Kappa^c^ | NA | 1.000 | 0.7308 | 0.5333
Star | Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise
Loop | No result produced^a^ | 0 comparisons | 0 of 1 comparisons | 0 of 1 comparisons | 0 of 1 comparisons
Loop | % agreement with Bayesian MTC^b^ | NA | 100 (1/1) | 100 (1/1) | 100 (1/1)
Loop | Kappa^c^ | NA | NA | NA | NA
Loop | Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise
One closed loop with adalimumab | No result produced^a^ | 0 of 3 comparisons | 0 of 3 comparisons | 0 of 3 comparisons | 0 of 3 comparisons
One closed loop with adalimumab | % agreement with Bayesian MTC^b^ | NA | 100 (3/3) | 100 (3/3) | 100 (3/3)
One closed loop with adalimumab | Kappa^c^ | NA | NA | NA | NA
One closed loop with adalimumab | Precision | Least precise | 3^rd^ most precise | 2^nd^ most precise | Most precise
One closed loop with etanercept | No result produced^a^ | 0 of 3 comparisons | 0 of 3 comparisons | 0 of 3 comparisons | 0 of 3 comparisons
One closed loop with etanercept | % agreement with Bayesian MTC^b^ | NA | 100 (3/3) | 100 (3/3) | 100 (3/3)
One closed loop with etanercept | Kappa^c^ | NA | 1.000 | 1.000 | 1.000
One closed loop with etanercept | Precision | 3^rd^ most precise | Least precise | 2^nd^ most precise | Most precise
Ladder | No result produced^a^ | 0 of 3 comparisons | 1 of 3 comparisons | 1 of 3 comparisons | 0 of 3 comparisons
Ladder | % agreement with Bayesian MTC^b^ | NA | 100 (2/2) | 100 (2/2) | 66.7 (2/32)
Ladder | Kappa^c^ | NA | 1.000 | NA | NA
Ladder | Precision | Least precise | 3^rd^ most precise | 2^nd^ most precise | Most precise

ACR 50 = American College of Rheumatology 50 percent response; MTC= mixed treatment comparison; NA = not applicable

a No result produced indicated the number of drug-drug comparisons for which the method was unable to produce a result, either because no studies had a common comparator or an insufficient number of studies had a common comparator.

b Percent agreement calculated only for drug-drug comparisons that both methods were able to produce a result. Results were considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian MTC) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment.

c Kappa was calculated only for comparisons when both methods were able to produce a result. Not applicable (NA) indicates that the statistical program was unable to calculate a kappa because of insufficient data (because there were fewer than two levels).

### Comparison of Bayesian MTC Results for the Full Networks With Bayesian MTC Results for Subcomponents

In this section, we present findings of the Bayesian MTC meta-analyses for each dataset for the full network and for subcomponents of the network. Because the data differ for each scenario, the measures are not intended to be directly comparable for the full network and for the various subcomponents of the network but are presented here to show model fit under each scenario. For example, the deviance information criterion should not be used to compare the fit of models using different datasets. The findings for the full network represent those for the complete literature on each set of medications (at the time of our CERs on each topic).19, 20 Those for the subcomponents examined hypothetical scenarios that would occur if the bodies of evidence were more limited.

#### Second-Generation Antidepressants: Binary Outcome

We ran MTC meta-analyses for the binary outcome of response to SGAs under five different network scenarios, the full network and four subcomponent network patterns: star, loop, one closed loop, and ladder (as described in the Methods chapter). Network figures in Appendix C detail the geometry of these subcomponents.

Measures of model fit are reported in Table 9. Estimates of between-study heterogeneity (tau squared) ranged from 0.12 to 0.44. When examining the total residual deviance for each scenario, all of them reasonably approximate the number of data points available, suggesting good model fit. The ladder and star pattern models most closely approximated the number of data points available.

Table 9 Measures of model fit for second-generation antidepressants for response

Statistic | Full Network | Star | Loop | One Closed Loop | Ladder
Total residual deviance (total number of data points available) | 135.3 (140) | 35.96 (36) | 25.64 (30) | 37.67 (42) | 39.36 (40)
Deviance information criterion | 259.45 | 246.67 | 188.42 | 271.67 | 270.31
Between-study heterogeneity | 0.2571 | 0.4427 | 0.1172 | 0.1196 | 0.3019

One feature of the Bayesian framework for MTC is the ability to directly calculate the probability that each drug is the best treatment. Table 10 shows the results of this statistic for the five scenarios. Because not every treatment was available in each network pattern, some comparisons were not applicable for every network pattern.

Table 10 Probability of best treatment for second-generation antidepressants for response

Statistic | Full Network | Star | Loop | One Closed Loop | Ladder
Bupropion | 0.005 | NA | NA | 0.057 | 0.034
Citalopram | 0.366 | NA | NA | 0.218 | 0.268
Desvenlafaxine | 0.023 | 0.019 | NA | NA | NA
Duloxetine | 0.000 | 0.005 | NA | NA | 0.002
Escitalopram | 0.090 | NA | NA | 0.056 | 0.110
Fluoxetine | 0.000 | 0.185 | 0.019 | 0.003 | 0.004
Fluvoxamine | 0.280 | 0.255 | NA | 0.202 | 0.262
Mirtazapine | 0.158 | NA | NA | 0.077 | 0.061
Nefazodone | 0.038 | 0.077 | NA | NA | NA
Paroxetine | 0.003 | 0.210 | 0.182 | 0.070 | 0.021
Sertraline | 0.003 | 0.007 | 0.798 | 0.317 | 0.069
Trazodone | 0.008 | NA | NA | 0.001 | 0.002
Venlafaxine | 0.028 | 0.243 | NA | NA | 0.168

NA = not applicable

For the full network, citalopram had the greatest probability of being the best treatment for achieving response (36.6%), followed by fluvoxamine. However, none of the treatments were particularly dominant to where we would have high confidence in that treatment truly having greater efficacy—as we might suggest if one reached a probability of 90 percent or more, for example. For the star network pattern, fluvoxamine had the greatest probability, followed by venlafaxine. But, again, none of the treatments were particularly dominant. The medication with the greatest probability of being the best treatment varied for each of the five scenarios. Only the one closed loop had a fairly dominant medication: sertraline had a probability of almost 80 percent for being the best treatment.

Given that not all of the comparisons were available in each scenario, we focused on the three drugs that were represented in each pattern: fluoxetine, paroxetine, and sertraline. Figure 5 shows the odds ratios and 95% credible intervals for the relative response of the antidepressants for each scenario. The full set of all pairwise comparisons is reported in Appendix D (Appendix Tables D-1, D-4, D-5, D-6, and D-7). Generally, the results show that the three drugs are not significantly different in odds of response. The two models with the least amount of connected data (star and ladder) also had the greatest heterogeneity and thus wider credible intervals around the mean. The response profiles for the loop and one closed loop mirrored the full network (with very similar point estimates) but found a significant difference between fluoxetine and sertraline, in part because of the lower between-studies heterogeneity of these reduced datasets.

Figure 5 Results of Bayesian MTC meta-analysis for five scenarios: odds ratio (95% credible interval) comparing fluoxetine, paroxetine, and sertraline for achieving response

CrI = credible interval; OR = odds ratio; vs. = versus

The figure is a forest plot displaying the results of Bayesian MTC meta-analysis for five network scenarios comparing fluoxetine, paroxetine, and sertraline for achieving response. The response is presented as a relative treatment effect for each pairwise comparison and is presented as an odds ratio and 95 percent credible interval (CrI). There are a total of 15 relative effects represented, one for each of the 5 network patterns, and the 3 three pairwise drug-drug comparisons. In the center of the figure, the odds ratios are presented as diamonds along the x-axis ranging from a scale of 0.25 to 2. Each diamond has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed. A vertical line running the center of the page for an odds ratio equal to one represents no difference between the two drugs. Odds ratios to the left of the line of no difference favor the second drug listed in the comparison; to the right of the line, they favor the first drug listed in the comparison. The odds ratios and 95 percent credible intervals for the full network are: fluoxetine versus paroxetine, OR 0.86 and 95 percent CrI 0.66 to 1.13, fluoxetine versus sertraline, OR 0.84 and 95 percent CrI 0.66 to 1.13, and paroxetine versus sertraline, OR 0.96 and 95 percent CrI 0.72 to 1.31. The odds ratios and 95 percent credible intervals for the star pattern are: fluoxetine versus paroxetine, OR 0.69 and 95 percent CrI 0.40 to 1.30, fluoxetine versus sertraline, OR 1.23 and 95 percent CrI 0.78 to 1.89, and paroxetine versus sertraline, OR 1.09 and 95 percent CrI 0.63 to 2.04. The odds ratios and 95 percent credible intervals for the closed loop pattern are: fluoxetine versus paroxetine, OR 0.83 and 95 percent CrI 0.64 to 1.11, fluoxetine versus sertraline, OR 0.76 and 95 percent CrI 0.61 to 0.96, and paroxetine versus sertraline, OR 0.90 and 95 percent CrI 0.68 to 1.25. The odds ratios and 95 percent credible intervals for the one closed loop pattern are: fluoxetine versus paroxetine, OR 0.83 and 95 percent CrI 0.65 to 1.10, fluoxetine versus sertraline, OR 0.77 and 95 percent CrI 0.63 to 0.96, and paroxetine versus sertraline, OR 0.91 and 95 percent CrI 0.68 to 1.27. The odds ratios and 95 percent credible intervals for the ladder pattern are: fluoxetine versus paroxetine, OR 0.91 and 95 percent CrI 0.66 to 1.30, fluoxetine versus sertraline, OR 0.73 and 95 percent CrI 0.45 to 1.32, and paroxetine versus sertraline, OR 0.78 and 95 percent CrI 0.45 to 1.59.

#### Second-Generation Antidepressants: Continuous Outcome

For the second illustration with the antidepressant data, response is now represented on a continuous scale by using mean change from baseline in HAM-D in each treatment arm. We ran MTC meta-analyses using a normal likelihood and identify link function for each of the five different network scenarios. Network figures in Appendix C detail the geometry of these scenarios.

Out of the 78 pairwise comparisons available in the full network, 21 were available in the star pattern, 3 in the loop, 21 in the one closed loop, and 28 in the ladder. The full results are reported in Appendix D (Tables D-2, D-8, D-9, D-10, and D-11). Although the point estimates vary across the patterns, likely because of the availability of direct head-to-head studies, the confidence intervals cross the line of no difference in all but one of the comparisons. As in the case of the binary outcome (response), there is little evidence from these data to support any important differences in the efficacy of the 13 antidepressants.

Measures of model fit are reported in Table 11. Estimates of between-study heterogeneity (tau squared) ranged from 0.86 to 1.97. For the total residual deviance for each scenario, the star, loop, and ladder most closely approximated the number of data points available, but fairly close approximations were found for all scenarios, suggesting good model fit.

Table 11 Measures of model fit for second-generation antidepressants for mean change from baseline in HAM-D

Statistic | Full Network | Star | Loop | One Closed Loop | Ladder
Total residual deviance (total number of data points available) | 86.93 (80) | 41.27 (40) | 18.81 (18) | 39.64 (38) | 26.71 (26)
Deviance information criterion | 254.08 | 120.76 | 59.866 | 122.637 | 75.126
Between-study heterogeneity | 0.8564 | 0.8637 | 1.974 | 1.683 | 1.192

As in the example with a binary outcome, we looked closer at three pairwise comparisons available under each scenario (Figure 6). Generally, the results show that the three drugs are not significantly different in mean change from baseline in HAM-D.

Figure 6 Results of Bayesian MTC meta-analysis for five scenarios: weighted mean difference (95% credible interval) comparing escitalopram, fluoxetine, and venlafaxine for mean change from baseline in HAM-D

CrI = credible interval; vs. = versus; WMD = weighted means difference

The figure is a forest plot displaying the results of Bayesian MTC meta-analysis for five network scenarios comparing escitalopram, fluoxetine, and venlafaxine for mean change from baseline in HAM-D. The response is presented as a relative treatment effect for each pairwise comparison and is presented as a mean difference and 95 percent credible interval (CrI). There are a total of 15 relative effects represented, one for each of the 5 network patterns, and the 3 three pairwise drug-drug comparisons. In the center of the figure, the mean differences are presented as circles along the x-axis ranging from a scale of -5 to 5. Each circle has a line running through it representing the width of the credible interval. On the right-hand side of the graph the mean differences and 95 percent credible intervals are listed. A vertical line running the center of the page for a mean difference equal to zero represents no difference between the two drugs. Estimates to the left of the line of no difference favor the first drug listed in the comparison; to the right of the line, they favor the second drug listed in the comparison. The weighted mean differences (WMD) and 95 percent credible intervals for the full network are: escitalopram versus fluoxetine, -0.88 and 95 percent CrI -2.40 to 0.48, escitalopram versus venlafaxine, 0.20 and 95 percent CrI -1.30 to 1.63, and fluoxetine versus venlafaxine, 1.08 and 95 percent CrI -0.14 to 2.41. The weighted mean differences (WMD) and 95 percent credible intervals for the star pattern are: escitalopram versus fluoxetine, 1.30 and 95 percent CrI -1.70 to 4.28, escitalopram versus venlafaxine, 3.12 and 95 percent CrI -0.61 to 6.85, and fluoxetine versus venlafaxine, 1.82 and 95 percent CrI -1.50 to 5.20. The weighted mean differences (WMD) and 95 percent credible intervals for the loop pattern are: escitalopram versus fluoxetine, -1.20 and 95 percent CrI -4.00 to 1.41, escitalopram versus venlafaxine, 0.65 and 95 percent CrI -2.90 to 3.94, and fluoxetine versus venlafaxine, 1.87 and 95 percent CrI -0.90 to 4.77. The weighted mean differences (WMD) and 95 percent credible intervals for the one closed loop pattern are: escitalopram versus fluoxetine, -1.20 and 95 percent CrI -4.00 to 1.41, escitalopram versus venlafaxine, 0.67 and 95 percent CrI -2.30 to 3.45, and fluoxetine versus venlafaxine, 1.85 and 95 percent CrI -0.50 to 4.31. The weighted mean differences (WMD) and 95 percent credible intervals for the ladder pattern are: escitalopram versus fluoxetine, -0.38 and 95 percent CrI -4.90 to 3.26, escitalopram versus venlafaxine, 2.32 and 95 percent CrI -2.90 to 6.80, and fluoxetine versus venlafaxine, 2.71 and 95 percent CrI -0.03 to 5.54.

#### Biologic DMARDs for Rheumatoid Arthritis: Binary Outcome

For the RA dataset, the majority of the trials were placebo-controlled; only one trial included a head-to-head comparison, between adalimumab and infliximab. Therefore, the choice of subcomponent network patterns was more limited than for the SGA dataset. We ran MTC meta-analyses on the binary outcome of ACR 50 response for five different network scenarios; the full network; and four sub-network patterns: star, loop, one closed loop, and ladder (as described in the Methods chapter). Network figures in Appendix C detail the geometry of these scenarios.

Measures of model fit are reported in Table 12. Estimates of between-study heterogeneity (tau squared) were very similar across scenarios (range 0.27 to 0.33). Total residual deviance data show that the full network and the loop most closely approximated the number of data points available, suggesting good model fit. The other scenarios had more sizeable differences between total residual deviance and the number of data points.

Table 12 Measures of model fit for biologic DMARDs for rheumatoid arthritis for achieving ACR 50

Statistic | Full Network | Star | Loop | One Closed Loop | Ladder
Total residual deviance (total number of data points available) | 65.54 (62) | 62.29 (40) | 17.01 (18) | 22.87 (38) | 16.03 (26)
Deviance information criterion | 394.56 | 374.04 | 110.95 | 149.89 | 101.45
Between-study heterogeneity | 0.3006 | 0.3193 | 0.3315 | 0.2668 | 0.3899

ACR 50 = American College of Rheumatology 50 percent response; DMARDs = disease-modifying antirheumatic drugs

Table 13 shows the probability that each drug is the best treatment for achieving ACR 50 response for each of the five scenarios. Because not every treatment was available in each network pattern, the probabilities for some treatments were not reported (i.e., not applicable) for some network patterns. For all five scenarios, etanercept had the greatest probability of being the best treatment for achieving ACR 50 response, with probabilities of 94.9 percent or higher.

Table 13 Probability of best treatment for biologic DMARDs for rheumatoid arthritis for achieving ACR 50

Statistic | Full Network | Star | Loop | One Closed Loop (ETA) | Ladder
Abatacept | 0.000 | 0.001 | 0.4526 | 0.001 | 0.000
Adalimumab | 0.003 | 0.003 | NA | NA | NA
Anakinra | 0.000 | 0.000 | NA | NA | NA
Etanercept | 0.953 | 0.949 | NA | 0.999 | 0.993
Golimumab | 0.040 | 0.041 | NA | NA | NA
Infliximab | 0.000 | 0.001 | 0.5473 | 0.001 | 0.007
Rituximab | 0.003 | 0.004 | NA | NA | NA
Tocilizumab | 0.000 | 0.000 | NA | NA | NA

DMARDs = disease-modifying antirheumatic drugs; ETA = etanercept; NA = not applicable

Given that not all of the comparisons were available in each scenario, we focused on the two drugs that are represented in each pattern. Figure 7 shows the odds ratios and 95 percent credible intervals for the relative response for each scenario. The full set of all pairwise comparisons is reported in Appendix D (Appendix Tables D-3, D-12, D-13, D-14, D-15, and D-16). Generally, the results show that the two drugs in Figure 7 are not significantly different in odds of ACR 50 response for four of the scenarios; the ladder found greater response for infliximab than for abatacept.

Figure 7 Results of Bayesian MTC meta-analysis for five scenarios: odds ratio (95% credible interval) comparing abatacept and infliximab for treatment response (ACR 50)

CrI = credible interval; OR = odds ratio; vs. = versus

The figure is a forest plot displaying the results of Bayesian MTC meta-analysis for five network scenarios comparing abatacept and infliximab for achieving ACR50 response. The response is presented as a relative treatment effect for each pairwise comparison and is presented as an odds ratio and 95 percent credible interval (CrI). There are a total of 5 relative effects represented, one for each of the 5 network patterns. In the center of the figure, the odds ratios are presented as circles along the x-axis ranging from a scale of 0.25 to 8. Each circle has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed. A vertical line running the center of the page for an odds ratio equal to one represents no difference between the two drugs. Odds ratios to the left of the line of no difference favor abatacept; to the right of the line, they favor infliximab. The odds ratio and 95 percent credible interval for the full network comparing abatacept versus infliximab is OR 1.06 and 95 percent CrI 0.61 to 1.74. The odds ratio and 95 percent credible interval for the star network comparing abatacept versus infliximab is OR 1.26 and 95 percent CrI 0.52 to 2.57. The odds ratio and 95 percent credible interval for the loop network comparing abatacept versus infliximab is OR 1.09 and 95 percent CrI 0.54 to 1.97. The odds ratio and 95 percent credible interval for the one closed loop network comparing abatacept versus infliximab is OR 1.07 and 95 percent CrI 0.59 to 1.78. The odds ratio and 95 percent credible interval for the ladder network comparing abatacept versus infliximab is OR 4.48 and 95 percent CrI 2.38 to 7.92.

## KQ 2 Meta-Regression With Bayesian MTC Meta-Analysis

This KQ aims to illustrate the use of meta-regression as a technique for exploring sources of heterogeneity of treatment effects in CERs. We examine two types of meta-regression in this KQ: one relates to exploring subgroup effects with a binary covariate and the other to exploring interaction effects with a continuous covariate. Our purpose here is to use meta-regression with Bayesian MTC meta-analysis within the context of two real-world scenarios from recent CERs and to examine two clinically important questions.

### Meta-Regression With a Subgroup Indicator Covariate

We hypothesized that differences in efficacy of SGAs may exist between older adults (≥55 years) and adults of any age. We used 72 trials of SGAs; 64 trials addressed efficacy in the general adult population and eight trials conducted exclusively in the older adult population. The outcome was treatment response as measured by 50 percent or greater improvement from baseline on the HAM-D. Figure 8 shows the evidence network for the 72 trials.

Figure 8 Evidence network for subgroup meta-regression to assess whether efficacy of second-generation antidepressants differs for older adults

The figure shows the second-generation antidepressants and placebo used in the full network analysis of response and the number of trials that contributed to each comparison. The drugs are as follows: fluoxetine, sertraline, fluvoxamine, duloxetine, bupropion, trazodone, venlafaxine, desvenlafaxine, citalopram, nefazodone, mirtazapine, paroxetine, escitalopram. There is also a placebo. Straight lines connect the drugs / placebo to each other. Four trials compared fluoxetine with sertraline. One trial compared fluoxetine with duloxetine. Seven trials compared fluoxetine with placebo. One trial compared fluoxetine with nefazodone. Eight trials compared fluoxetine with venlafaxine. Five trials compared fluoxetine with paroxetine. One trial compared fluoxetine with mirtazapine. Two trials compared fluoxetine with bupropion. Three trials compared sertraline with bupropion. One trial compared sertraline with trazodone. Eight trials compared sertraline with placebo. One trial compared sertraline with paroxetine. Three trials compared sertraline with venlafaxine. One trial compared sertraline with nefazodone. One trial compared fluvoxamine with placebo. One trial compared fluvoxamine with citalopram. One trial compared bupropion with trazodone. Three trials compared bupropion with placebo. Two trials compared trazodone with mirtazapine. One trial compared trazodone with paroxetine. One trial compared mirtazapine with paroxetine. Five trials compared paroxetine with placebo. Three trials compared paroxetine with duloxetine. One trial compared paroxetine with nefazodone. One trial compared paroxetine with escitalopram. Three trials compared venlafaxine with placebo. One trial compared venlafaxine with escitalopram. One trial compared escitalopram with fluoxetine. One trial compared escitalopram with placebo. Three trials compared escitalopram with duloxetine. One trial compared escitalopram with citalopram. One trial compared duloxetine with desvenlafaxine. Five trials compared desvenlafaxine with placebo. Eight trials compared duloxetine with placebo. Two trials compared nefazodone with placebo.

For this analysis, we used a random effects logistic regression model, including the appropriate adjustment for correlations within multi-arm trials. Convergence was checked via trace plots, and posterior means were calculated after 100,000 iterations following a burn-in of 20,000 iterations. We used a common (single) interaction term. Figure 9 shows the odds ratios of treatment response for each of the SGAs, relative to placebo, within each age subgroup.

Figure 9 Odds ratios (95% credible interval) of treatment response for second-generation antidepressants, by patient population

CrI = credible interval; OR = odds ratio; vs. = versus

The figure is a forest plot displaying the results of Bayesian MTC meta-analysis for treatment response of 13 second generation antidepressants, stratified by adult and older adult population. The response is presented as a relative treatment effect for each drug versus placebo and is presented as an odds ratio and 95 percent credible interval (CrI). There are a total of 26 relative effects represented, one for each of the adult and older adult population sets. In the center of the figure, the odds ratios are presented as circles along the x-axis ranging from a scale of 0.25 to 4. Each circle has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed. A vertical line running the center of the page for an odds ratio equal to one represents no difference between the two drugs. Odds ratios to the left of the line of no difference favor placebo; to the right of the line they favor the drug. The odds ratios and 95 percent credible intervals for the thirteen antidepressants among adults are: buproprion, OR 1.76 and 95 percent CrI 1.29 to 2.35; citalopram, OR 2.49 and 95 percent CrI 1.42 to 4.10; desvenlafaxine, OR 2.01 and 95 percent CrI 1.48 to 2.67; duloxetine, OR 1.80 and 95 percent CrI 1.44 to 2.23; escitalopram, OR 2.40 and 95 percent CrI 1.78 to 3.17; fluoxetine, OR 1.69 and 95 percent CrI 1.36 to 2.08; fluvoxamine, OR 2.91 and 95 percent CrI 1.46 to 5.27; mirtazapine, OR 2.03 and 95 percent CrI 1.25 to 3.14; nefazodone, OR 1.98 and 95 percent CrI 1.26 to 2.99; paroxetine, OR 1.97 and 95 percent CrI 1.53 to 2.51; sertraline, OR 1.95 and 95 percent CrI 1.58 to 2.38; trazodone, OR 1.41 and 95 percent CrI 0.86 to 2.19; and venlafaxine, OR 2.17 and 95 percent CrI 1.66 to 2.78. The odds ratios and 95 percent credible intervals for the thirteen antidepressants among older adults are: buproprion, OR 1.27 and 95 percent CrI 0.82 to 1.87; citalopram, OR 1.78 and 95 percent CrI 1.00 to 2.92; desvenlafaxine, OR 1.46 and 95 percent CrI 0.89 to 2.22; duloxetine, OR 1.30 and 95 percent CrI 0.87 to 1.86; escitalopram, OR 1.73 and 95 percent CrI 1.13 to 2.51; fluoxetine, OR 1.22 and 95 percent CrI 0.85 to 1.67; fluvoxamine, OR 2.08 and 95 percent CrI 1.00 to 3.87; mirtazapine, OR 1.45 and 95 percent CrI 0.86 to 2.29; nefazodone, OR 1.43 and 95 percent CrI 0.81 to 2.33; paroxetine, OR 1.42 and 95 percent CrI 0.99 to 1.96; sertraline, OR 1.40 and 95 percent CrI 0.98 to 1.93; trazodone, OR 1.00 and 95 percent CrI 0.59 to 1.60; and venlafaxine, OR 1.56 and 95 percent CrI 1.04 to 2.23.

Within the general adult population, efficacy was supported for all antidepressants with the exception of trazodone. When estimating these effects for the older adult population within the same meta-regression model, the efficacy for each drug appears to be diminished with only escitalopram and venlafaxine maintaining statistical superiority compared with placebo. This trend is supported by the interaction effect estimate of -0.34 (95% CrI, -0.696 to 0.006). This represents, on average, a -0.34 reduction in the log odds of response (not for the odds ratio scale). While approaching marginal statistical significance, the interaction estimate indicates a trend toward lower response rates in the older adult population. We compared the meta-regression model of 72 studies with the main adult analysis including 64 studies. The estimates for between-study heterogeneity were similar, although slightly reduced in the model containing the additional older adult studies (Table 14). Both model estimates of total residual deviance were appropriate when compared with the number of data points available in each analysis, suggesting a good model fit in each case.

Table 14 Measures of model fit for main analysis and meta-regression

Statistic | Main Adult Analysis (n=64) | Meta-Regression Including Older Adults (n=72)
Total residual deviance (total number of datapoints available) | 135.3 (140) | 153.8 (158)
DIC | 928.73 | 933.38
Between-study heterogeneity | 0.2571 | 0.2506

DIC = Deviance Information Criterion

### Meta-Regression With a Continuous Covariate

We hypothesized that differences in efficacy of treatments for RA may exist for patients with varying durations of disease. Longer disease durations were hypothesized to be associated with higher levels of treatment response. We aimed to test the effects of this covariate (mean disease duration) on the findings from our recent CER—with our Bayesian MTC meta-analysis finding that etanercept resulted in greater treatment response than most other biologic DMARDs.

Twenty-eight of the 31 trials included in our Bayesian MTC meta-analysis reported data on mean disease duration (in years). Both trials that did not report data on mean disease duration compared etanercept with placebo. If disease duration was presented as only an arm-level mean, the average of the arms was taken for the trial-level mean. All eight biologic DMARDs were represented in the 28 trials (Figure 10). The mean trial-level disease duration ranged from 3.9 to 13 years.

Figure 10 Evidence network for continuous covariate meta-regression to assess whether efficacy of biologic DMARDs differs for patients with longer disease duration

The figure shows the biologic DMARDs and placebo used in the continuous covariate meta-regression analysis of ACR50 response and the number of trials that contributed to each comparison. The drugs are as follows: abatacept, infliximab, golimumab, adalimumab, tocilizumab, rituximab, etanercept, and anakinra. There is also a placebo. Straight lines connect the drugs / placebo to each other. One trial compared abatacept with infliximab. Three trials compared abatacept with placebo. Six trials compared infliximab with placebo. Two trials compared golimumab with placebo. Seven trials compared adalimumab with placebo. Four trials compared tocilizumab with placebo. Two trials compared rituximab with placebo. Two trials compared etanercept with placebo. Three trials compared anakinra with placebo.

A random effects logistic regression model was used, including the appropriate adjustment for correlations within multi-arm trials. The model was fitted assuming a common interaction effect for all treatments. Convergence was checked via trace plots, and posterior means were taken after 100,000 iterations following a burn-in of 20,000 iterations.

Table 15 shows the probability of best treatment with and without the meta-regression covariate. The interaction effect was found to be statistically important and supported the hypothesis of increased treatment response with increased disease duration. When including the effect of mean disease duration, the probability that etanercept was the best treatment dropped from 0.961 to 0.678, indicating that treatments with higher reported response rates, including etanercept, may have appeared to be more efficacious due to the inclusion of studies enrolling patient populations with longer disease durations.

Table 15 Interaction effect and probability of best treatment

Probability of Best Treatment | No Covariate | With Disease Duration Covariate
Interaction Effect | NA | 0.093 (95% CrI: 0.005 to 0.182)
Abatacept | 0.001 | 0.001
Adalimumab | 0.003 | 0.007
Anakinra | 0.000 | 0.000
Etanercept | 0.961 | 0.678
Golimumab | 0.033 | 0.286
Infliximab | 0.000 | 0.002
Rituximab | 0.003 | 0.015
Tocilizumab | 0.001 | 0.010

CrI = credible interval; NA = not applicable

Figure 11 presents odds ratios for etanercept response compared with other biologic DMARDs from the model with and without the covariate. When examining the relative effects of etanercept compared with the other biologic DMARDs, we see that when controlling for years of disease severity, the relative efficacy of etanercept is reduced. While trending in the direction of greater efficacy compared with all of the other biologic DMARDs, statistical significance was only reached for the comparison with anakinra. However, even with the muted effect of etanercept in the model controlling for disease duration level, when looking at the probability of best treatment it appears the only other biologic with competing efficacy is golimumab. When predicting the estimated odds ratios for different disease durations, we found that odds ratios for etanercept compared with placebo ranged from 7.35 with one year of RA to 14.99 with 10 years of the disease.

Figure 11 Odds ratios (95% credible interval) of treatment response for Etanercept compared with other biologic DMARDs, with and without disease duration covariate

CrI = credible interval; OR = odds ratio; vs. = versus

The figure is a forest plot displaying the results of Bayesian MTC meta-analysis for treatment response of etanercept compared with other biologic DMARDs, stratified by the presence of a covariate in the model controlling for disease duration. The relative treatment effect is presented as an odds ratio and 95 percent credible interval (CrI). There are a total of 14 relative effects represented. In the center of the figure, the odds ratios are presented as circles along the x-axis ranging from a scale of 0.25 to 16. Each circle has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed. A vertical line running the center of the page for an odds ratio equal to one represents no difference between the two drugs. Odds ratios to the left of the line of no difference favor the first drug listed in the comparison; to the right of the line they favor the second drug. The odds ratios and 95 percent credible intervals for the model including the covariate are: etanercept versus abatacept, OR 3.62 and 95 percent CrI 0.92 to 10.58; etanercept versus adalimumab, OR 2.88 and 95 percent CrI 0.78 to 8.11; etanercept versus anakinra, OR 4.74 and 95 percent CrI 1.08 to 14.43; etanercept versus golimumab, OR 1.08 and 95 percent CrI 0.34 to 6.33; etanercept versus infliximab, OR 2.27 and 95 percent CrI 0.85 to 9.71; etanercept versus rituximab, OR 2.14 and 95 percent CrI 0.73 to 10.72; etanercept versus tocilizumab, OR 1.93 and 95 percent CrI 0.72 to 8.34. The odds ratios and 95 percent credible intervals for the model with no covariate are: etanercept versus abatacept, OR 5.20 and 95 percent CrI 1.99 to 11.86; etanercept versus adalimumab, OR 3.49 and 95 percent CrI 1.37 to 7.71; etanercept versus anakinra, OR 7.11 and 95 percent CrI 2.45 to 17.01; etanercept versus golimumab, OR 2.38 and 95 percent CrI 0.93 to 8.76; etanercept versus infliximab, OR 4.14 and 95 percent CrI 1.99 to 11.13; etanercept versus rituximab, OR 3.75 and 95 percent CrI 1.52 to 12.80; and etanercept versus tocilizumab, OR 3.58 and 95 percent CrI 1.72 to 9.81.

## KQ 3 Stability of the Bayesian MTC Analyses for Different Numbers of Studies and Network Pattern Assumptions

The motivation for this question arose from uncertainty about how the number of studies per comparison and different network scenarios interact with the ability of the model to produce valid results. We aimed to explore this question through an empirical study with simulated data. We anticipated the simulation study would provide insights about how many studies are needed in order for the Bayesian MTC meta-analysis to produce valid results. We first describe the results from our equivalent efficacy dataset and then describe those from our superior efficacy dataset.

### Equivalent Efficacy Scenario

Table 16 shows the mean, standard deviation, and standard error of the probability that each drug was the best in the MTC meta-analysis runs for the 1,000 sample datasets for each network pattern and each available number of studies for the equivalent efficacy scenario. In the equivalent efficacy scenario, the pre-determined mean response (standard deviation) of drug one (placebo) was 0.10 (0.03); the pre-determined mean response (standard deviation) for each of drugs two, three, and four was 0.50 (0.05).

Table 16 Simulation results: Probability of best treatment under equivalent efficacy scenario

Network Pattern | Number of Studies for Each Drug-Drug Comparison | Drug 1 (placebo) Mean (SD, SE) | Drug 2 Mean (SD, SE) | Drug 3 Mean (SD, SE) | Drug 4 Mean (SD, SE)
Star | 1 | 0.01 (0.004, 0.004) | 0.34 (0.045, 0.045) | 0.33 (0.045, 0.045) | 0.32 (0.048, 0.048)
Star | 2 | 2 × 10^-3^ (2 × 10^-4^, 1 × 10^-4^) | 0.34 (0.115, 0.081) | 0.34 (0.112, 0.079) | 0.33 (0.116, 0.082)
Star | 3 | 1 × 10^-6^ (1 × 10^-5^, 6 × 10^-6^) | 0.33 (0.131, 0.076) | 0.33 (0.133, 0.077) | 0.34 (0.136, 0.079)
Star | 5 | 0.00 (0.000, 0.000) | 0.33 (0.144, 0.064) | 0.34 (0.141, 0.063) | 0.33 (0.139, 0.062)
Star | 10 | 0.00 (0.000, 0.000) | 0.33 (0.153, 0.048) | 0.34 (0.150, 0.047) | 0.33 (0.150, 0.047)
Loop | 1 | 0.03 (0.009, 0.009) | 0.24 (0.054, 0.054) | 0.34 (0.049, 0.049) | 0.38 (0.040, 0.040)
Loop | 2 | 5 × 10^-4^ (5 × 10^-4^, 4 × 10^-4^) | 0.27 (0.152, 0.107) | 0.33 (0.140, 0.099) | 0.40 (0.116, 0.082)
Loop | 3 | 3 × 10^-6^ (2 × 10^-5^, 1 × 10^-5^) | 0.27 (0.174, 0.100) | 0.33 (0.168, 0.097) | 0.40 (0.132, 0.076)
Loop | 5 | 0.00 (0.000, 0.000) | 0.27 (0.190, 0.085) | 0.33 (0.180, 0.080) | 0.40 (0.139, 0.062)
Loop | 10 | 0.00 (0.000, 0.000) | 0.27 (0.201, 0.064) | 0.33 (0.190, 0.060) | 0.40 (0.150, 0.047)
One Closed Loop | 1 | 0.01 (0.004, 0.004) | 0.25 (0.077, 0.077) | 0.25 (0.077, 0.077) | 0.49 (0.004, 0.004)
One Closed Loop | 2 | 1 × 10^-4^ (2 × 10^-4^, 1 × 10^-4^) | 0.26 (0.126, 0.089) | 0.25 (0.126, 0.089) | 0.49 (0.005, 0.004)
One Closed Loop | 3 | 7 × 10^-7^ (1 × 10^-5^, 6 × 10^-6^) | 0.25 (0.137, 0.079) | 0.26 (0.137, 0.079) | 0.49 (0.005, 0.003)
One Closed Loop | 5 | 0.00 (0.000, 0.000) | 0.25 (0.146, 0.065) | 0.26 (0.146, 0.065) | 0.49 (0.006, 0.003)
One Closed Loop | 10 | 0.00 (0.000, 0.000) | 0.25 (0.148, 0.047) | 0.26 (0.148, 0.047) | 0.49 (0.006, 0.002)
Ladder | 1 | 0.11 (0.019, 0.019) | 0.30 (0.054, 0.054) | 0.24 (0.062, 0.062) | 0.35 (0.053, 0.053)
Ladder | 2 | 0.003 (0.002, 0.001) | 0.37 (0.169, 0.120) | 0.28 (0.186, 0.132) | 0.36 (0.168, 0.119)
Ladder | 3 | 4 × 10^-5^ (1 × 10^-4^, 6 × 10^-5^) | 0.37 (0.195, 0.113) | 0.28 (0.218, 0.126) | 0.35 (0.195, 0.113)
Ladder | 5 | 0.00 (0.000, 0.000) | 0.36 (0.209, 0.093) | 0.29 (0.234, 0.105) | 0.35 (0.203, 0.091)
Ladder | 10 | 0.00 (0.000, 0.000) | 0.36 (0.225, 0.071) | 0.30 (0.246, 0.078) | 0.34 (0.215, 0.068)

SD = standard deviation; SE = standard error

In the equivalent efficacy scenario, we would expect to find that there are no differences between drugs two, three, and four, while drug one (placebo) should clearly be found the least efficacious. Table 17 shows the bias of the simulation results, which is the difference between observed and expected probabilities. For this data scenario, the bias ranged from 0.00 to 0.16, the latter being mainly in the one closed loop pattern. In the following bullets, we summarize our findings:

- For the star and ladder network patterns the correct conclusion was generally supported for each scenario (with varying numbers of studies for each drug-drug comparison). Even in cases where one drug had a slightly higher probability than expected, the difference was not sufficiently large to lead to the wrong conclusion (that one drug was superior to other drugs).
- The loop and one closed loop patterns had higher predicted means for the fourth drug in the network, even though drug four is not more efficacious than drugs two or three. The one closed loop pattern found drug four to be the best drug in almost half of the iterations.
- Findings of analyses when one study was available for each comparison were generally very similar to findings when more studies (two, three, five, or ten) were available. Differences between results with one study available and those with ten studies available were often 0.01 or less and were never greater than 0.06 (for drugs two and three in the ladder pattern).

Table 17 Bias of simulation results: Difference between observed and expected probability of best treatment under equivalent efficacy scenario

Expected Value | | 0.00 | 0.33 | 0.33 | 0.33
Network pattern | Number of Studies for Each Drug-Drug Comparison | Drug 1 (placebo) Bias | Drug 2 Bias | Drug 3 Bias | Drug 4 Bias
Star | 1 | 0.01 | 0.01 | 0.00 | 0.01
Star | 2 | 0.00 | 0.01 | 0.01 | 0.00
Star | 3 | 0.00 | 0.00 | 0.00 | 0.01
Star | 5 | 0.00 | 0.00 | 0.01 | 0.00
Star | 10 | 0.00 | 0.00 | 0.01 | 0.00
Loop | 1 | 0.03 | 0.09 | 0.01 | 0.05
Loop | 2 | 0.00 | 0.06 | 0.00 | 0.07
Loop | 3 | 0.00 | 0.06 | 0.00 | 0.07
Loop | 5 | 0.00 | 0.06 | 0.00 | 0.07
Loop | 10 | 0.00 | 0.06 | 0.00 | 0.07
One Closed Loop | 1 | 0.01 | 0.08 | 0.08 | 0.16
One Closed Loop | 2 | 0.00 | 0.07 | 0.08 | 0.16
One Closed Loop | 3 | 0.00 | 0.08 | 0.07 | 0.16
One Closed Loop | 5 | 0.00 | 0.08 | 0.07 | 0.16
One Closed Loop | 10 | 0.00 | 0.08 | 0.07 | 0.16
Ladder | 1 | 0.11 | 0.03 | 0.09 | 0.02
Ladder | 2 | 0.00 | 0.04 | 0.05 | 0.02
Ladder | 3 | 0.00 | 0.04 | 0.05 | 0.02
Ladder | 5 | 0.00 | 0.03 | 0.04 | 0.02
Ladder | 10 | 0.00 | 0.03 | 0.03 | 0.01

### Superior Efficacy Scenario

Table 18 shows the mean, standard deviation, and standard error of the probability that each drug was the best in the MTC meta-analysis runs for the 1,000 sample datasets for each network pattern and each available number of studies for the superior efficacy scenario. In the superior efficacy scenario, the pre-determined mean response (standard deviation) for each of drugs one, two, and three was 0.20 (0.04); the predetermined mean response (standard deviation) of drug four was 0.80 (0.04).

Table 18 Simulation results: Probability of best treatment under superior efficacy scenario

Network Pattern | Number of Studies for Each Drug-Drug Comparison | Drug 1 Mean (SD, SE) | Drug 2 Mean (SD, SE) | Drug 3 Mean (SD, SE) | Drug 4 Mean (SD, SE)
Star | 1 | 0.03 (0.009, 0.009) | 0.13 (0.016, 0.016) | 0.13 (0.017, 0.017) | 0.71 (0.023, 0.023)
Star | 2 | 8 × 10^-4^ (0.008, 0.006) | 0.01 (0.006, 0.004) | 0.010 (0.006, 0.004) | 0.98 (0.012, 0.008)
Star | 3 | 2 × 10^-5^ (5× 10^-4^, 3× 10^-4^) | 2 × 10^-4^ (5× 10^-4^, 3× 10^-4^) | 0.0002 (0.0005, 0.0002) | 0.9995 (0.001, 6× 10^-4^)
Star | 5 | 0.00 (0.000, 0.000) | 4 × 10^-7^ (7× 10^-6^, 3× 10^-6^) | 9 × 10^-7^ (9× 10^-6^, 4× 10^-6^) | 0.9999 (1× 10^-5^, 5× 10^-6^)
Star | 10 | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 1.00 (0.00, 0.00)
Loop | 1 | 0.05 (0.011, 0.011) | 0.08 (0.016, 0.016) | 0.16 (0.020, 0.020) | 0.71 (0.025, 0.025)
Loop | 2 | 0.001 (0.001, 7× 10^-4^) | 0.004 (0.004, 0.003) | 0.01 (0.010, 0.007) | 0.98 (0.014, 0.10)
Loop | 3 | 2 × 10^-5^ (7× 10^-5^, 4× 10^-5^) | 0.0001 (0.0003, 0.0002) | 0.0005 (0.001, 6× 10^-4^) | 0.999 (0.001, 6× 10^-4^)
Loop | 5 | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 1.4 × 10^-6^ (1× 10^-5^, 5× 10^-6^) | 0.99999 (1× 10^-5^, 5× 10^-6^)
Loop | 10 | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 1.00 (0.00, 0.00)
One Closed Loop | 1 | 0.17 (0.076, 0.076) | 0.17 (0.079, 0.079) | 0.17 (0.077, 0.077) | 0.49 (0.003, 0.003)
One Closed Loop | 2 | 0.17 (0.118, 0.083) | 0.17 (0.119, 0.084) | 0.17 (0.120, 0.085) | 0.50 (0.005, 0.004)
One Closed Loop | 3 | 0.16 (0.129, 0.074) | 0.17 (0.131, 0.076) | 0.17 (0.129, 0.074) | 0.50 (0.005, 0.003)
One Closed Loop | 5 | 0.16 (0.132, 0.059) | 0.17 (0.133, 0.059) | 0.16 (0.131, 0.059) | 0.50 (0.005, 0.002)
One Closed Loop | 10 | 0.17 (0.143, 0.045) | 0.17 (0.137, 0.043) | 0.16 (0.136, 0.043) | 0.50 (0.007, 0.002)
Ladder | 1 | 0.17 (0.023, 0.023) | 0.09 (0.018, 0.018) | 0.05 (0.011, 0.011) | 0.69 (0.030, 0.030)
Ladder | 2 | 0.01 (0.009, 0.006) | 0.004 (0.004, 0.003) | 0.001 (0.001, 7× 10^-4^) | 0.98 (0.013, 0.009)
Ladder | 3 | 6 × 10^-4^ (0.001, 6× 10^-4^) | 1 × 10^-4^ (0.0003, 0.0002) | 2 × 10^-5^ (7× 10^-5^, 4× 10^-5^) | 0.999 (0.001, 6× 10^-4^)
Ladder | 5 | 1 × 10^-6^ (1× 10^-5^, 5× 10^-6^) | 1 × 10^-7^ (3 ×10^-6^, 1× 10^-6^) | 0.00 (0.000, 0.000) | 1.0 (0.00, 0.00)
Ladder | 10 | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 0.00 (0.000, 0.000) | 1.0 (0.00, 0.00)

SD = standard deviation; SE = standard error

In the superior data scenario, we would expect to find no differences between drugs one, two, and three, while drug four should clearly be found to be the best treatment. Table 19 shows the bias of the simulation results for this data scenario. The differences between observed and expected probabilities ranged from 0.00 to 0.51, again with the bias in the one closed loop pattern being the most pronounced. In the following bullets, we summarize our findings:

- For each scenario (with varying numbers of studies and network patterns), the correct conclusion was generally supported, with one notable exception. In the one closed loop pattern, the model failed to definitively find drug four to be the most efficacious.
- Generally, there were no significant differences between the estimates generated with 2, 3, 5, or 10 studies available for each comparison.
- For the scenarios with one study available per comparison, although probabilities of best treatment differed numerically compared with those scenarios with more studies available, the findings were still indicative of superior efficacy of drug four. For drug four, differences between estimates (of the probability of being the best treatment) from analyses with one study available per comparison and those from analyses with two studies available per comparison ranged up to 0.29.

Table 19 Bias of simulation results: Difference between observed and expected probability of best treatment under superior efficacy scenario

Expected Value | | 0.00 | 0.00 | 0.00 | 1.00
Network Pattern | Number of Studies for Each Drug-Drug Comparison | Drug 1 (placebo) Bias | Drug 2 Bias | Drug 3 Bias | Drug 4 Bias
Star | 1 | 0.03 | 0.13 | 0.13 | 0.29
Star | 2 | 0.00 | 0.01 | 0.01 | 0.02
Star | 3 | 0.00 | 0.00 | 0.00 | 0.00
Star | 5 | 0.00 | 0.00 | 0.00 | 0.00
Star | 10 | 0.00 | 0.00 | 0.00 | 0.00
Loop | 1 | 0.05 | 0.08 | 0.16 | 0.29
Loop | 2 | 0.00 | 0.00 | 0.01 | 0.02
Loop | 3 | 0.00 | 0.00 | 0.00 | 0.00
Loop | 5 | 0.00 | 0.00 | 0.00 | 0.00
Loop | 10 | 0.00 | 0.00 | 0.00 | 0.00
One Closed Loop | 1 | 0.17 | 0.17 | 0.17 | 0.51
One Closed Loop | 2 | 0.17 | 0.17 | 0.17 | 0.50
One Closed Loop | 3 | 0.16 | 0.17 | 0.17 | 0.50
One Closed Loop | 5 | 0.16 | 0.17 | 0.16 | 0.50
One Closed Loop | 10 | 0.17 | 0.17 | 0.16 | 0.50
Ladder | 1 | 0.17 | 0.09 | 0.05 | 0.31
Ladder | 2 | 0.01 | 0.00 | 0.00 | 0.02
Ladder | 3 | 0.00 | 0.00 | 0.00 | 0.00
Ladder | 5 | 0.00 | 0.00 | 0.00 | 0.00
Ladder | 10 | 0.00 | 0.00 | 0.00 | 0.00

The estimates from tables 16 and 18 are also presented graphically, as histograms in Appendix F.