# References

1 Agency for Healthcare Research and Quality. What Is Comparative Effectiveness Research. Rockville, MD. http://www.effectivehealthcare.ahrq.gov/index.cfm/what-is-comparative-effectiveness-research1/. May 3, 2012.
2 Bucher HC, Guyatt GH, Griffith LE, et al. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. Jun. 1997;50(6):683-91. [pmid: 9250266].
3 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
4 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
5 Dias S, Sutton AJ, Welton NJ, et al. NICE DSU Technical Support Document 3: Heterogeneity: subgroups, meta-regression, bias and bias-adjustment. Report by the Decision Support Unit. 2011. http://www.nicedsu.org.uk/TSD3%20Heterogeneity_final%20report_docx.pdf. May 4, 2012.
6 Dias S, Welton NJ, Sutton AJ, et al. A Generalised Linear Modelling Framework for Pairwise and Network Meta-analysis of Randomised Controlled Trials. Report by the Decision Support Unit. Updated August 2011. http://www.nicedsu.org.uk/TSD2%20ES%20-%2005_05_11_FINAL_updated%20Aug2011.pdf. May 4, 2012.
7 Jansen JP, Crawford B, Bergman G, et al. Bayesian meta-analysis of multiple treatment comparisons: an introduction to mixed treatment comparisons. Value Health. Sep-Oct. 2008;11(5):956-64. [pmid: 18489499].
8 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
9 Cooper NJ, Peters J, Lai MC, et al. How valuable are multiple treatment comparison methods in evidence-based health-care evaluation?. Value Health. Mar-Apr. 2011;14(2):371-80. [pmid: 21296599].
10 Mills EJ, Bansback N, Ghement I, et al. Multiple treatment comparison meta-analyses: a step forward into complexity. Clin Epidemiol. 2011;3:193-202. [pmid: 21750628].
11 Cipriani A, Furukawa TA, Salanti G, et al. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. Feb. 28. 2009;373(9665):746-58. [pmid: 19185342].
12 Li T, Puhan MA, Vedula SS, et al. Network meta-analysis-highly attractive but more methodological research is needed. BMC Med. 2011;9:79. [pmid: 21707969].
13 Padwal R, Klarenbach S, Wiebe N, et al. Bariatric surgery: a systematic review and network meta-analysis of randomized trials. Obes Rev. Aug. 2011;12(8):602-21. [pmid: 21438991].
14 Jansen JP, Fleurence R, Devine B, et al. Interpreting indirect treatment comparisons and network meta-analysis for health-care decision making: report of the ISPOR Task Force on indirect treatment comparisons good research practices: part 1. Value Health. 2011:417-28. [pmid: 21669366].
15 Higgins JP, Whitehead A. Borrowing strength from external trials in a meta-analysis. Stat Med. Dec. 30. 1996;15(24):2733-49. [pmid: 8981683].
16 Lu G, Ades AE. Assessing evidence inconsistency in mixed treatment comparisons. Journal of the American Statistical Association. 2006;101(474):447-59.
17 Hoaglin DC, Hawkins N, Jansen JP, et al. Conducting indirect-treatment-comparison and network-meta-analysis studies: report of the ISPOR Task Force on indirect treatment comparisons good research practices: part 2. Value Health. Jun. 2011;14(4):429-37. [pmid: 21669367].
18 Higgins JPT, Jackson D, Barrett JK, et al. Consistency and inconsistency in network meta-analysis: concepts and models for multi-arm studies. Research Synthesis Methods. 2012;3(2):98-110.
19 Gartlehner G, Hansen RA, Morgan LC, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center, Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC012-EF. Agency for Healthcare Research and Quality. Rockville, MD. December. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
20 Donahue KE, Jonas DE, Hansen RA, et al. Drug Therapy for Rheumatoid Arthritis in Adults: An Update. Comparative Effectiveness Review No. 55. (Prepared by RTI-UNC Evidence-based Practice Center under Contract No. 290-02-0016-I.) AHRQ Publication No. 12-EHC025-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Salanti G, Kavvoura FK, Ioannidis JP. Exploring the geometry of treatment networks. Ann Intern Med. Apr. 1. 2008;148(7):544-53. [pmid: 18378949].
22 Canadian Agency for Drugs and Technologies in Health (CADTH). Biological response modifier agents for adults with rheumatoid arthritis. Ottawa, ON. July. 2010. http://cadth.ca/media/pdf/Biologics_for_RA_TRP_Final_Recommendations_e.pdf. May 4, 2012.
23 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
24 Kasper S, de Swart H, Friis Andersen H. Escitalopram in the treatment of depressed elderly patients. Am J Geriatr Psychiatry. Oct. 2005;13(10):884-91. [pmid: 16223967].
25 Roose SP, Sackeim HA, Krishnan KR, et al. Antidepressant pharmacotherapy in the treatment of depression in the very old: a randomized, placebo-controlled trial. Am J Psychiatry. Nov. 2004;161(11):2050-9. [pmid: 15514406].
26 Schneider LS, Nelson JC, Clary CM, et al. An 8-week multicenter, parallel-group, double-blind, placebo-controlled study of sertraline in elderly outpatients with major depression. Am J Psychiatry. Jul. 2003;160(7):1277-85. [pmid: 12832242].
27 Tollefson GD, Bosomworth JC, Heiligenstein JH, et al. A double-blind, placebo-controlled clinical trial of fluoxetine in geriatric patients with major depression. The Fluoxetine Collaborative Study Group. Int Psychogeriatr. Spring. 1995;7(1):89-104. [pmid: 7579025].
28 Aletaha D, Strand V, Smolen JS, et al. Treatment-related improvement in physical function varies with duration of rheumatoid arthritis: a pooled analysis of clinical trial results. Ann Rheum Dis. Feb. 2008;67(2):238-43. [pmid: 17644550].
29 Aletaha D, Ward MM. Duration of rheumatoid arthritis influences the degree of functional improvement in clinical trials. Ann Rheum Dis. Feb. 2006;65(2):227-33. [pmid: 15975967].
30 Anderson JJ, Wells G, Verhoeven AC, et al. Factors predicting response to treatment in rheumatoid arthritis: the importance of disease duration. Arthritis Rheum. Jan. 2000;43(1):22-9. [pmid: 10643696].
31 Salanti G. Indirect and mixed-treatment comparison, network, or multiple-treatments meta-analysis: many names, many benefits, many concerns for the next generation evidence synthesis tool. Research Synthesis Methods. 2012;3(2):80-97.
32 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. Jul. 1992;45(7):769-73. [pmid: 1619456].
33 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011.
34 Cohen J. A coefficient of agreement for nominal scales. Educ Psychol Meas. 1960;20(1):37-46.
35 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33(1):159-74. [pmid: 843571].
36 Borenstein M, Hedges LV, Higgins JPT, et al. Introduction to Meta-Analysis. Cambridge, UK. Wiley. 2009.
37 McCullagh P, Nelder JA. Generalized Linear Models, volume 37 of (Monographs on Statistics and Applied Probability. 2nd ed. London. Chapman & Hall. 1989.
38 Spiegelhalter DJ, Abrams KR, Myles J. Bayesian Approaches to Clinical Trials and Health-Care Evaluation. Chichester. Wiley. 2004.
39 Parmigiani G. Modeling in medical decision making: A Bayesian approach. Chichester. Wiley. 2002.
40 Gelman A, Rubin DB. Inference from iterative simulation using multiple sequences. Statistical Science. 1992;7(4):457-511.
41 Spiegelhalter DJ, Best NG, Carlin BP, et al. Bayesian measures of model complexity and fit. J Royal Statistical Society. 2002;64(4):583-639.
42 Carlin BP, Louis TA. Bayesian Methods for Data Analysis. 3rd ed. Boca Raton. Chapman & Hall. 2008.
43 Harbord RM, Higgins JPT. Meta-regression in Stata. Stata J. 2008;8(4):493-519.
44 Cooper NJ, Sutton AJ, Morris D, et al. Addressing between-study heterogeneity and inconsistency in mixed treatment comparisons: Application to stroke prevention treatments in individuals with non-rheumatic atrial fibrillation. Stat Med. 2009;28(14):1861-81. [pmid: 19399825].
45 Morton SC, Adams JL, Suttorp MJ, et al. Meta-regression Approaches: What, Why, When, and How? Technical Review 8. (Prepared by Southern California–RAND Evidence-based Practice Center, under Contract No 290-97-0001). AHRQ Publication No. 04-0033. Rockville, MD. Agency for Healthcare Research and Quality. March. 2004.
46 Dias S, Welton NJ, Sutton AJ, et al. NICE DSU Technical Support Document 2: A Generalised Linear Modelling Framework for Pairwise and Network Meta-Analysis of Randomised Controlled Trials. last updated August 2011. 2011. http://www.nicedsu.org.uk. May 4, 2012.
47 Ades AE, Mavranezouli I, Dias S, et al. Network meta-analysis with competing risk outcomes. Value in Health. 2010;13(8).