# Methods

In this chapter, we first describe the data from two real-world bodies of trial literature that we used for our analyses for Key Questions (KQs) 1 and 2. We then describe the methods used for each KQ. The focus of this report is on mixed treatment comparison (MTC) meta-analysis implemented in a Bayesian framework; for comparison, we performed adjusted indirect comparisons using four different approaches with a frequentist framework (each described below).

The National Institute for Health and Clinical Excellence (NICE) Decision Support Unit has released several Technical Support Documents (TSDs) detailing use of MTC in a Bayesian framework, including several illustrative examples with annotated WinBUGS code. We implemented the methods illustrated in TSD 2^6^ and TSD 3^5^ under different scenarios for the MTC meta-analyses described below. For both of our recent comparative effectiveness reviews (CERs) including MTC meta-analyses, we used WinBUGS Version 1.4.3, a Bayesian software package that uses Markov chain Monte Carlo (MCMC) techniques. WinBUGS code used for analyses is available in Appendix A.

## Data Included in This Report

For this report, as described in the introduction, we used datasets from MTC meta-analyses from two recent CERs. An underlying assumption for the validity of MTC meta-analyses is transitivity (sometimes referred to as similarity).31 Assessing whether the included studies had sufficiently comparable compositions was undertaken in the original CERs rather than for this report. Briefly, to assess similarity and to determine whether to combine studies in MTC meta-analyses for the CERs, we evaluated the populations, interventions, comparators, outcomes, timing, and settings of the trials under consideration.

### Dataset 1 Second-Generation Antidepressants

For this report, we extracted one binary and one continuous outcome from the evidence base of our CER on second-generation antidepressants (SGAs). Our binary outcome was treatment response as measured by at least a 50 percent improvement from baseline on the Hamilton Rating Scale for Depression (HAM-D). We recalculated response rates for each study using the number of all randomized patients as the denominator to reflect a true ITT analysis. With this approach we attempted to correct variations in results of modified ITT analyses encountered in individual studies. A total of 64 studies with adequate reporting of treatment response were included in subsequent analyses. Eight additional studies were identified in the older adult populations (age 55 or older) and used in the meta-regression for KQ 2. Characteristics of the included studies and data used in the meta-analyses are listed in Appendix Table B-1. The dataset includes many multi-arm trials (Appendix Table B-1). Additional descriptions of study populations and other eligibility criteria can be found in the full report.19

Our continuous outcome was mean change from baseline to endpoint on the HAM-D. For studies not reporting a variance for mean change from baseline, we calculated one using the baseline and endpoint variances and assumed a correlation of 0.5. We chose a value of 0.5 for the correlation coefficient as a reasonable assumption for the similarity of baseline and endpoint values across patients, because it assumes neither a weak nor strong correlation. In lieu of more complete reporting, it has been suggested that a value of 0.5 is a reasonable assumption.32, 33 We included a total of 40 studies in the analyses for this outcome; data and characteristics of the included studies are listed in Appendix Table B-2. The dataset includes several multi-arm trials (Appendix Table B-2).

### Dataset 2 Biologic Disease-Modifying Antirheumatic Drugs for Treatment of Rheumatoid Arthritis

We extracted one binary and one continuous outcome from the studies included in our CER on biologic DMARDs and other treatments for RA. The binary outcome considered was treatment response as measured by achievement of ACR 50 after 12 weeks of treatment. Again, we recalculated response rates for each study using the number of all randomized patients as the denominator to reflect a true ITT analysis. With this approach we attempted to correct variations in results of modified ITT analyses encountered in individual studies. A total of 31 studies covering eight biologic DMARDs with adequate reporting of treatment response were included. Characteristics and data of the included studies are shown in Appendix Table B-3 below. The dataset includes one multi-arm trial (Appendix Table B-3).

We also extracted a continuous outcome, mean change from baseline in Health Assessment Questionnaire Disability Index (HAQ-DI); however, because few eligible studies reported adequate data, we were not able to perform any meaningful MTC meta-analysis on the continuous outcome.

## KQ 1 Comparison of Bayesian MTC Meta-Analysis With Frequentist Indirect Methods

Our objectives for this KQ were to examine how results of Bayesian MTC methods compare with commonly used frequentist indirect methods and how Bayesian MTC methods perform for different types of evidence network patterns. We chose four analytic methods—Bayesian MTC meta-analysis, frequentist meta-regression, the Bucher method, and frequentist logistic regression. These methods were chosen because they are among the most common approaches considered when conducting CERs. For both of our datasets (SGAs and biologic DMARDs), we compared the findings from these four methods—first, for the full networks; second, for subcomponents of the full networks representing specific evidence network patterns (star, loop, one closed loop, and ladder). To compare the four analytic methods, we used several measures: (1) the proportion of drug-drug comparisons (out of the total possible number of comparisons) for which each method was unable to calculate a result, either because of model convergence issues or the lack of a common comparator; (2) the percent agreement, with findings considered to agree if both methods produced a non-statistically significant (for frequentist methods) or unimportant (for Bayesian methods, based on 95% credible intervals) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment; (3) the precision of findings—assessed by comparing the width of credible intervals and confidence intervals; and (4) kappa statistics. The kappa statistic is a measure of inter-rater agreement34 that attempts to take into account agreement beyond chance. It can range between -1 and 1, but usually ranges from zero to 1, as kappa is negative when the observed agreement is less than chance. When the observed agreement exceeds chance agreement, kappa is positive, with its magnitude reflecting the strength of agreement. Landis and Koch propose the following as guidelines for strength of agreement for the kappa coefficient: <0.20 = poor, 0.21 to 0.40 = fair, 0.41 to 0.60 = moderate, 0.61 to 0.80 = good, and 0.81 to 1.00 = very good.35 For each comparison (e.g., Bayesian MTC vs. frequentist meta-regression), we calculated kappa statistics using SAS version 9.2. We did not calculate kappa statistics for comparisons in which either method had less than two levels (i.e., when all results for that method found no statistically significant or important difference for each drug-drug comparison).

Finally, we describe measures of model fit for the Bayesian MTC analyses for the full networks and for subcomponents. For all dichotomous data, we used odds ratios, and for all continuous data, we used weighted mean differences as outcome measures.

### Bayesian Mixed Treatment Comparison Meta-Analysis

For all Bayesian MTC meta-analyses included in this report, we used the methods developed in TSDs 2 and 3, which detail use of the generalized linear modeling (GLM) framework for Bayesian MTC and use of meta-regression to explore sources of heterogeneity, respectively. We used random effects models in this report because in meta-analyses of randomized controlled trials, we assume the study effect is sampled from a distribution of effect sizes.36 Because studies will not include exactly the same mix of participants or carry out the interventions in an identical way, there may be different underlying effect sizes for different studies.

GLM theory37 allows for likelihood-based statistical inference. It is also a flexible approach because it can be constructed to model data arising from a large range of distributions within the exponential family, allowing us to model various binary and continuous outcomes that we would encounter in conducting CERs. GLM theory can be implemented in both frequentist and Bayesian frameworks. Spiegelhalter et al.38 make the case for a Bayesian framework, stating that such an approach is more flexible, efficient, and useful. MTC could in theory be implemented in a frequentist framework, but the literature reflects a preference for a Bayesian framework, in part because of the availability of WinBUGS code that has been developed for this purpose.6, 39 Reasons to use a Bayesian framework (rather than a frequentist approach) include inferential superiority and modeling flexibility. Whether Bayesian approaches have inferential superiority is a contentious subject and may have little to do with the reason the Bayesian MTC methods are used more widely. Modeling flexibility, however, is likely a major reason the Bayesian approach is more popular. With WinBUGS, one has simply to specify the likelihood and the prior distributions; the estimation is handled by MCMC methods that are now fairly robust. With maximum likelihood estimation using a frequentist approach, some of the likelihoods can be very challenging to maximize and perhaps amenable to approximate solutions only.

In a Bayesian framework, specification of prior distributions accompanies the specification of the likelihoods, in addition to the data. The complete model specification is detailed below. For this report, binary outcomes are treatment response measured by the number of people achieving a prespecified level in each arm. We used noninformative (flat) prior distributions throughout the report, which allow the data to drive the posterior distributions, in absence of more informative priors. This choice follows the recommendations laid out in TSD 2^6^ and in absence of rationale for specifying informative priors with these data. For all analyses, we modeled study effect and treatment effect parameters by noninformative (flat) prior distributions that were Normal (0, 10000). For the heterogeneity of the random-effects model, we used a uniform prior distribution with sufficiently large variance. Unless otherwise specified, we discarded the first 20,000 simulations to allow for model convergence, and we used an additional 100,000 simulations in estimating the posterior probabilities. Satisfactory convergence was verified by trace plots, monitoring the Monte Carlo error, and with Gelman-Rubin diagnostics.40 If multi-arm studies were available, we included the appropriate adjustments to the likelihood to account for correlations between the treatment differences. We did not use statistical methods to assess inconsistency.

For the initial values to start the Markov chain simulations, we chose values that were relatively widely dispersed. We reviewed previous publications and TSDs 2 and 3 to help inform our choice of initial values. To help determine whether our choice of initial values influenced findings, we conducted some sensitivity analyses for our MTC analyses of the full networks by changing the initial values (e.g., for our ACR 50 MTC analysis, we [1] changed the initial values from chains of 0 and −3 to chains of 1 and −3 and [2] added chains with a variety of values ranging from −5 to 7). The sensitivity analyses did not produce appreciably different results.

#### Bayesian Mixed Treatment Comparison: Model Specification

Most of the data used in this report consisted of outcomes that measured the number of events, in all cases treatment response, occurring out of the total number of patients. These types of data were assumed to arise from a binomial likelihood. The likelihood was specified as

r_i,k_ ∼ Binomial(p_i,k_, n_i,k_)

where r_i,k_ is the number achieving treatment response out of the total number of patients in each arm and p_i,k_ is the probability of treatment response, and where i denotes trial number and k denotes each arm of the trial. For this likelihood, the logit link function was used to map the probability of treatment response onto plus and minus infinity. The logit link was specified as follows:

logit(p_i,k_) = μ_i_ + δ_i,k_I_(k ≠ 1)_

The trial-specific log-odds ratios from a random effect model come from a common distribution, δ_i,k_ ∼ N(d_k_, σ^2^), where d represents the relative treatment effect and σ^2^ is the common variance term.

In all cases, parameters were given vague or noninformative prior distributions. The choice of the uniform prior between 0 and 5 reflects a between-study variability that allows for a wide range of treatment effects.

Prior specification:

μ_i_ ∼ Normal (0, 10000) d_k_ ∼ Normal (0, 10000) σ ∼ Uniform (0, 5)

For continuous outcomes, the data were assumed to arise from a normal likelihood, and under generalized linear modeling theory, the model specified above becomes a normal likelihood with the identity link function. The observed data y_i,k_ arise from a normal distribution with mean θ_i,k_ and variance se_i , k_^2^ .

y_i , k_ = N ( θ_i , k_ , se_i , k_^2^ )

For these data, the prior specifications were identical to the ones used with the dichotomous data.

For KQ 2, in order to introduce a dichotomous study-level covariate to the logistic regression model above, the model was simply extended to include a covariate x_i_. The model specification and resulting WinBUGS code were taken from the Decision Support Unit's TSD 3. Again, the subscript i denotes trials and the subscript k refers to the arms within a trial. The full model structure is specified below.

r_i,k_ ∼ Binomial (p_i,k_, n_i,k_) logit(p_i,k_) = μ_i_ + δ_i,k_I_(k≠1)_ + (β_k_ − β_1_)x_i_ β_1_ = 0

Prior specification:

In addition to the above, now a vague normal prior on the common covariate effect

β_k_ ∼ Normal (0, 10000)

Again, the extension to introducing a continuous covariate results in the same model above, but to improve the efficiency of estimation, the continuous covariate was centered around its mean, as shown below. All other pieces of the model specification remained the same. Changes to the logistic model are shown below.

logit(p_i,k_) = μ_i_ + δ_i,k_I_(k≠1)_ + (β_k_ − β_1_) (x_i_ − mean(x_i_))

#### Model Statistics

When conducting the Bayesian MTC meta-analyses, we output several statistics to compare relative efficacy and assess model fit, as described below.

##### Outcome Measures

We assessed relative efficacy between treatments with odds ratios and 95 percent credible intervals for dichotomous data, and with mean differences and 95 percent credible intervals for continuous data. We also calculated the probability that each treatment was the best, by ranking the drugs on a relative scale. Because we used random effects models, we also output the estimate of the between-studies standard deviation in each scenario.

##### Model Fit

We assessed model fit with the Deviance Information Criterion (DIC) and the posterior mean of the total residual deviance.41 Deviance measures the fit of the model to the data using the likelihood function. A good model fit is indicated by a total residual deviance approximately equal to the number of data points available. The DIC is a statistic that measures Bayesian model fit and penalizes the deviance by the model complexity. When comparing two DIC values, a difference of 5 or more is regarded as a meaningful difference.42

### Frequentist Indirect Comparisons

We compared the results from Bayesian MTC meta-analyses with three frequentist indirect methods for binary data and two frequentist indirect methods for continuous data. We used only two for continuous data because logistic regression cannot be used with continuous data. We chose these methods because they are among the most common indirect analyses currently used in CERs and because they have been validated with data simulation.3

#### Bucher Method

For one indirect comparisons approach, we used methods proposed by Bucher and colleagues.2 To derive indirect comparisons of two treatments, the method compares the magnitude of treatment effects of two interventions relative to a common comparator. For binary data, we calculated the pooled odds ratios for each drug of interest relative to a common comparator using random effects meta-analyses (as proposed by DerSimonian and Laird). For continuous data we used weighted mean differences.

Specifically, as described by Bucher and colleagues,2 to compare treatment A versus B, we first estimated the pooled odds ratios for treatment A versus C and treatment B vs. C with:

OR_AC_ = ((p_A_)/(1 − p_A_))/((p_C_)/(1 − p_C_))

OR_BC_ = ((p_B_)/(1 − p_B_))/((p_C_)/(1 − p_C_))

where p is the probability of response to treatment (i.e., p_A_ is the probability of response given treatment A). The odds ratios for the indirect comparison of treatments A versus B may then be estimated by taking the ratio of the two odds ratios:

OR_AB_ = (OR_AC_)/(OR_BC_)

The indirect comparison may be calculated as follows:

ln(OR_AB_) = ln(OR_AC_) − ln (OR_BC_)

Given the odds ratios (OR_AC_ and OR_BC_) are estimated based on different studies and therefore are independent, the variance for this effect is the pooled variance:

Variance(ln(OR_AB_)) = Variance(ln(OR_AC_)) + Variance(ln(OR_BC_))

For continuous outcomes we used the same analytic approach without conversion to a logarithmic scale. The effect measure of choice for continuous outcomes was the weighted mean difference of the treatments relative to a common comparator. We conducted all analyses with Comprehensive MetaAnalysis version 2.2.050 (Biostat, Englewood NJ).

#### Frequentist Meta-Regression

For the frequentist meta-regression approach, we followed a two-step process to indirectly estimate the comparative efficacy of two drugs. We first conducted random effects meta-analyses as proposed by DerSimonian and Laird,4 combining two drugs of interest to estimate an overall pooled effect.

Second, we estimated the comparative treatment effects between two drugs with random effects meta-regression. We implemented this method using the Stata “metareg” command (Harbord & Higgins, 2008).43 Stata version 11 was used for all frequentist meta-regression analyses. The unit of analysis for meta-regression was a study. The predictor in the regression model was a binary variable indicating the presence or absence of the drug of interest. Random effects meta-regression extends random effects meta-analysis by replacing the mean with a linear predictor. The response to treatment given study i is:

y_i_ = x_i_β + u_i_ + ε_i_

where

- i = study,
- y_i_ = response to treatment in study i,
- x_i_ = study-level covariate,
- β = fixed effect parameter,
- u_i_ = treatment effect in study i, and
- ε_i_ = error.

For dichotomous outcomes, y_i_ is the log odds ratio and for continuous outcomes, y_i_ is the weighted mean difference.

The treatment effects may vary across studies and assumed to be normally distributed where τ^2^ is the between study variance:

u_i_ ∼ N(0, τ^2^)

Errors are also assumed to be normally distributed:

ɛ_i_ ∼ N(0, σ^2^)

#### Logistic Regression Modeling

The logistic regression modeling approach is similar to the meta-regression approach; however, an individual rather than a study is the unit of analysis. For the indirect comparisons using logistic regression, we incorporated the approach outlined by Glenny et al. (2005).3 We constructed datasets with the number of participants responding to the treatment and the number of participants not responding to the treatment matching those reported in each study. In other words, if a study reported that 100 of 300 patients responded to treatment A and 150 of 300 patients responded to treatment B, we constructed a dataset with a total of 600 patients (100 responders and 200 nonresponders receiving treatment A and 150 responders and 150 nonresponders receiving treatment B). We then estimated logistic regression models using PROC GLIMMIX in SAS version 9.2 with a dichotomous outcome of response versus no response to treatment and including treatment as a fixed effect and study as a random effect.

PROC GLIMMIX is used for computing generalized linear mixed effect models and can be applied to various types of outcome variables. The general form of the model is:

E(Y|γ) = g^−1^ (Xβ + Zγ)

where

- Y = outcome variable,
- X = matrix of fixed effects,
- β = vector of fixed effect parameters,
- γ = matrix of random effect parameters,
- Z = matrix of random effect, and
- g = link function.

In this model, E(Y| γ) represents the expected value for the outcome based on the model. In our analyses, we used a mixed effects model where the outcome (Y) was response to treatment (yes vs. no) with treatment as a fixed effect (X) and study as a random effect (Z) as shown below:

E(Response to treatment|γ) = g^−1^ (β_0_ + β_1_Treatment_1_ … + β_j_Treatment_j_ + γ_1_Study_1_ … . + γ_i_Study_i_)

where i is the number of studies and j is the number of treatments.

Because the outcome is dichotomous, we selected a logit link function and when applied to the equation, the final model is:

E ( Response to treatment | γ ) = (1)/(1 + e^− ( β_0_ + β_0_ + β_1_ Treatment_1_ … + β_j_ Treatment_j_ + γ_1_ Study_1_ … + γ_i_ Study_i_ )^)

A binomial variance function was specified along with an unstructured covariance matrix that permits the estimation of all elements of the variance/covariance matrix without constraints. The indirect comparisons were estimated within these models by applying contrast statements to compute odds ratios comparing response between two treatments of interest.

#### Handling of Multi-Arm Studies in Frequentist Analyses

None of the frequentist indirect methods used in this report accounted for correlations between treatment responses within multi-arm studies. This is an advantage of the Bayesian MTC methods when multi-arm studies are included, as the correction to the likelihood is easily implemented in the available code. However, in most cases this was not an issue because multi-arm studies were generally not included when conducting the indirect frequentist analyses.

### Choice of Network Patterns

As part of KQs 1 and 2, we aimed to investigate how Bayesian MTC methods perform for different network patterns. An evidence network's geometry may be shaped by clinical context, regulatory pressure, or other factors. The evidence network may change over time, as new drugs are added to the market or different comparators are chosen.21 We chose four simple network patterns as the basis for comparisons within this report: star, loop, one closed loop, and ladder (see Introduction). These four patterns reflect different scenarios that exist in the context of real-world data. Within each of the real-world datasets used, we selected a subset of the studies for each of the four patterns. Although many different subsets of data were available for each pattern that we could have selected, we selected examples that maximized the amount of data available for each sub-network. We selected one of each type of network pattern for each of the datasets. Because of limited time and resources, we could not evaluate every possible network pattern within each dataset. Appendix C illustrates the network patterns evaluated. Other choices could have been made, such as one reflecting the entry of drugs into the market or chronologically by publication date, but for the purposes of this report, we believe that an approach maximizing the amount of data available is the most useful.

## KQ 2 Meta-Regression

Our objective for this KQ was to introduce study-level covariates in the models used with Bayesian MTC meta-analysis to explore heterogeneity, attempting to answer two clinically important questions—one for each of our datasets. For the SGAs dataset, we conducted meta-regression by assessing whether efficacy differed in trials that enrolled older adults compared with trials that enrolled adults of any age. For the biologic DMARDs dataset, we conducted meta-regression using mean disease duration of subjects enrolled in each study as a continuous covariate to determine whether treatment efficacy varies by disease duration of RA. The two analyses involved exploring two different types of covariates in the meta-regression: one relates to exploring subgroup effects with a binary covariate (for SGAs) and the other to exploring interaction effects with a continuous covariate (disease duration of RA).

There is often a need to explore heterogeneity in treatment effects in terms of another variable, and many software packages facilitate meta-regression for pair-wise meta-analysis. But, until recently, there has not been a readily available process for Bayesian MTC in WinBUGS. Incorporation of covariates into network models was first discussed by Cooper et al.,44 describing three different types of models for covariates. The NICE Decision Support Unit published TSD 3^5^ to illustrate the use of different types of meta-regression within Bayesian MTC (using the work of Cooper et al. as a template). Bayesian MTC allows us to incorporate all the available evidence into one analysis, which, combined with the ability to explore potential effect modifiers or confounders, can be a powerful tool when conducting CERs.

We used the methods described in TSD 3, which build on the generalized linear modeling framework established in TSD 2. TSD 3 describes three general approaches to meta-regression models in a multiple treatment context: separate and unrelated interaction terms for each treatment, exchangeable and related interaction terms, and one single interaction effect for all treatments. We used the latter. WinBUGs code and the datasets used are provided in Appendix A. For exploring subgroup effects through a meta-regression, a trial-level binary indicator was created to indicate study population. This indicator variable was added to the random effects logistic regression model used in KQ 1. In this way, the interaction term describes the effect of the population on the outcome. In the second example, a continuous covariate was added to the same random effects logistic regression model, assuming a common covariate effect for each treatment. The continuous covariate was centered at its mean value to improve model convergence. The magnitude and direction of the interaction term was examined in each example, along with its effect on the odds of treatment response in each case.

### Meta-Regression With a Subgroup Indicator Covariate: Efficacy of SGAs and Older Adults

From our report on SGAs, eight trials provided data on efficacy in older adult patients. We hypothesized that differences in efficacy may exist between studies enrolling older adults (≥55 years) and those enrolling adults of any age. We explored this by introducing a covariate to the model that indicated the subgroup population. The analysis included 72 trials; 64 trials addressing efficacy in the adult population and eight trials conducted in the older adult population. The outcome was treatment response as measured by 50 percent or greater improvement from baseline on the HAM-D. We intended to test the interaction effect and compare the odds ratios for the treatments within each population. One advantage of this type of meta-regression is that it allows for the exploration of differences within one model, rather than performing multiple analyses separately and comparing results qualitatively.

### Meta-Regression With a Continuous Covariate: Efficacy of Biologic DMARDs and Disease Duration of Rheumatoid Arthritis

Our recent CER on biologic DMARDs included a total of 31 studies in the MTC meta-analysis (see descriptions above and data from the included studies provided in Appendix Table B-3). The outcome was response as measured by ACR 50 after a minimum treatment period of 12 weeks. The trials included RA patients who failed methotrexate, a first-line therapy, but were naïve to treatment with a biologic DMARD. One trial-level factor hypothesized to have an effect on treatment response is mean disease duration of RA. Longer disease durations are hypothesized to be associated with higher levels of treatment response. We aimed to test the effects of this covariate (mean disease duration) on our findings (with etanercept yielding greater treatment response than most other biologic DMARDs: see Introduction).

## KQ 3 Methods Section for Simulation Study

Because of inherent limitations when using real-world data, we proposed a simulation study to investigate the role of the number of studies available for each comparison on the MTC meta-analysis model's ability to detect true relative efficacy under different network patterns. The motivation for a simulation study arose from uncertainty about how the number of studies available for each comparison affects the ability of the model to produce valid results and whether this varied under different network patterns. In performing Bayesian MTC meta-analyses for CERs, the question of whether there are enough studies to make valid conclusions about comparative efficacy often arises. Many times, only one study is identified that links two treatments (or a treatment and placebo) together in a network. We hypothesized that findings may vary depending on the underlying data structure (i.e., network pattern).

In order to assess the ability of the Bayesian MTC method to produce valid results under the four network patterns, we first created simulated datasets comprising two scenarios for comparative efficacy. Simulated datasets will lend flexibility in choosing the number of studies available for each comparison and also allow us to determine the true comparative efficacy a priori. The basic process of the simulation is illustrated in Figure 4. We restricted the simulations to four treatments in each case and set the sample size within each study to be 100 patients per treatment arm. Our outcome was a dichotomous measure of treatment response (1 = response, 0 = no response).

Figure 4 Simulation study design

The figure is a flow chart displaying the iterative steps taken in the simulation study. At the top of the figure are two cylinders representing the master datasets created from separate 10,000 binomial draws, called the equivalent efficacy and superior efficacy datasets, respectively. Below the master datasets are diagrams of the four network patterns: star, loop, one closed loop, and ladder. The network diagrams represent that the second step in the process was the select sub-datasets from the master datasets that represent each of these patterns. Below that is a box with the title, Select Number of Studies, and the box contains the different number of studies that are sampled with each of the network patterns above it: 1 study per comparison, 2 studies per comparison, 3 studies per comparison, 5 studies per comparison, and 10 studies per comparison. Below this step is a box representing that the Bayesian Mixed Treatment Comparison (MTC) meta-analysis that was run a total of 40,000 times, each time using the random effects logistic regression model detailed in the methods section. Finally, the last step is shown by a triangle representing the metric that was output from each of these MTC runs, the probability of best treatment.

Two master simulated datasets were created in SAS to test the method in one case where analyses should not find important differences and in another case where analyses should find important differences. The first dataset is a scenario of equivalent efficacy of three drugs compared with placebo. A dataset of 10,000 “studies” and four treatments was created by sampling from the binomial distribution so that placebo had a mean response of 0.10, and drugs 2 through 4 had a mean response of 0.50. In this way, drugs 2 through 4 have equivalent efficacy, but all have greater efficacy than placebo.

The second of the two datasets is a scenario of superior efficacy of one drug compared with three other drugs. Again, a dataset of 10,000 “studies” and four treatments was created by sampling from the binomial distribution so that drugs 1 through 3 had a mean response of 0.20, and drug 4 had a mean response of 0.80. In this case, drug 4 is superior to the other drugs in the network, which all have equal efficacy compared with each other. We did not include any multi-arm trials in either of the simulated datasets.

Next, to address variations in the number of studies available for each comparison, we selected five cases: 1, 2, 3, 5, and 10 studies per comparison. That is, the link connecting any two drugs is based on 1, 2, 3, etc., studies. We fixed this number so that the overall number of studies per link is the same for each drug comparison. We sampled successive studies from the two master datasets to produce 1,000 sample datasets for each of the four network patterns (star, loop, one closed loop, and ladder) and the five cases, resulting in a total of 40,000 simulated datasets. The datasets were then submitted to the Bayesian MTC meta-analysis model used in KQ 1. In each model run, there was a burn-in of 5,000 iterations, followed by 15,000 iterations from which we monitored and output the probability that each drug was the best (i.e., most efficacious). Satisfactory convergence was verified by trace plots and by monitoring the Monte Carlo error. Convergence was generally achieved quickly (as might be expected with each individual dataset being fairly small, with just four drugs). The output of 1,000 “best” statistics for each pattern by case (determined by number of studies for each comparison) formed a distribution to allow us to assess the model estimates versus the predetermined treatment efficacy. To estimate bias, we computed the difference between the percentage of times a drug was considered most effective based on the models and the expected percentage based on the assumptions used to generate the data. The SAS code and WinBUGs code used to generate the master datasets and Bayesian models are provided in Appendix A.