# Introduction

## Background

Comparative effectiveness reviews (CERs) often aim to compare the benefits and harms of multiple available approaches for treating a health condition1 with the ultimate goal of informing clinical practice and other decisionmaking. To this end, analysts conducting CERs aim to find studies conducting direct head-to-head comparisons. However, direct head-to-head evidence on competing interventions is often scant. As a result, several methods to conduct indirect comparisons have been proposed.2-7 These include meta-regression, logistic regression, the Bucher method,2-4 and, more recently, Bayesian mixed treatment comparison (MTC) meta-analysis.5-7

MTC meta-analysis is a relatively new methodology.8 Various other terms have been used to describe the approach, including multiple treatment comparisons9-11 and network meta-analysis.12, 13 Terminology has evolved to where most experts in that field now refer to the broad area of comparison of different treatments as network meta-analysis and restrict the use of MTC to describe methods that explicitly look at combining direct and indirect evidence.14 One of the most compelling reasons to use MTC meta-analysis is that it allows for the combination of both direct head-to-head and indirect evidence (e.g., placebo-controlled trials) in one modeling framework. The use of all potentially relevant available evidence is an appealing feature for analysts, because other methods rely solely on one type of evidence. In addition, unlike other indirect analysis methods, MTC meta-analysis allows all relevant comparisons to be made through a single analysis, providing the information to calculate an effect size for each comparison of interest and to rank treatments based on the probability of being the best treatment.

The history of MTC meta-analysis dates back to 1996 when Higgins and Whitehead first described likelihood-based methods for indirect comparisons, focusing on Bayesian methods and providing an illustration of the methodology using data from 26 clinical trials that investigated the prevention of cirrhosis using beta-blockers and sclerotherapy.15 Lu and Ades subsequently published additional information on the theoretical underpinnings of the MTC method,8 as well as methods for assessing evidence inconsistency16 (which is not addressed in this report). But more research is needed to better understand how these methods operate in real-world scenarios. As investigators conducting systematic reviews use these methods and continue to develop new techniques based on these methods, it is important for us to have a better understanding of how these methods compare with other indirect methods and how MTC meta-analyses perform in various situations.

Relatively little information on the validity of MTC meta-analysis exists (in comparison with other indirect methods or for various types of evidence networks), and further research is needed.12, 17 Some analysts have validated frequentist approaches for indirect comparisons using artificial/simulated data.3

One underlying question is whether the extra complexity of Bayesian MTC meta-analyses is worth the investment. MTC meta-analysis requires greater statistical expertise and, until recently, could only be run using programs (e.g., WinBUGS) that are unfamiliar to many analysts. (Recently, Higgins et al. published an example of likelihood-based MTC using Stata).18 In contrast, several of the frequentist methods for indirect comparisons can be conducted by analysts with less statistical expertise and using programs that are more familiar. It is important to gain a better understanding of the consequences of choosing various analytic approaches. Some questions include the following: Do results differ for various analytic approaches? Do certain methods yield more precise estimates? Do the findings and validity of various analytic approaches vary depending on the evidence network pattern?

We used MTC meta-analyses in two recent CERs for the Agency for Healthcare Research and Quality (AHRQ)—one on second-generation antidepressants (SGAs)19 and one on treatments for rheumatoid arthritis (RA).20 In this report, we use the real-world literature from these two reports to address our objectives and Key Questions (KQs).

## Evidence Networks

An evidence network refers to the linkage of treatment comparisons that exists in the literature for a given population. It can take on many shapes or patterns.21, 22 The basic premise underlying MTC methods is that the network must be a connected one. A network can include any of the four patterns in Figure 1. A network pattern can resemble a star, with one common comparator at the center and other treatments connected through this comparator. This is a common scenario for pharmacotherapies, because randomized controlled trials (RCTs) often include only drug comparisons with placebo (and no direct head-to-head comparisons). Another pattern is a loop design, where all drugs or treatments are connected to one another through one other treatment. A third common pattern is a variation on this loop design, but this network also includes one or more drugs or treatments outside of the loop and is referred to as one closed loop. Another network pattern resembles a ladder, with no treatment compared with any other treatment more than once.

Figure 1 Evidence network patterns

The figure displays four common evidence network patterns: star, loop, one closed loop, and ladder. From left to right is a graphical representation of each pattern, with boxes representing drugs, and lines connecting boxes that represent a drug-drug comparison present in the literature. For the star pattern, boxes representing drug 1, drug 2, drug 3, and drug 4 are connected by lines to a box representing placebo. The individual drugs are not connected to one another in the star pattern. The second pattern, called a loop pattern, has drug 1 connected by lines to drug 2 and drug 3; drug 2 is connected with a line to both drug 1 and drug 3; and drug 3 is connected by a line to both drug 1 and drug 2. In this way, each drug is connected in a circle. The third pattern is called a one closed loop pattern and is identical to the previous loop pattern, but with another drug 4 connected with a line to drug 2. This drug 4 in the one closed loop pattern represents an offshoot of the circle created by the loop pattern. The final pattern is called the ladder pattern. For this pattern, drug 2 is connected to drug 1 and drug 3. Drug 1 and drug 3 are not connected to each other in the ladder, so that each drug is only connected to one other drug.

## Second-Generation Antidepressants

Our report on SGAs compared the benefits and harms of 13 SGAs approved for use in the United States19 (Table 1).

Table 1 Second-generation antidepressants approved for use in the United States

Generic Name | U.S. Trade Name^a^ | Dosage Forms | Therapeutic Classification
Bupropion^b^ | Wellbutrin^®^; Wellbutrin SR^®^; Wellbutrin XL^®^ | 75, 100 mg tabs; 100, 150, 200 mg SR tabs 150, 300 mg XL tabs | Other
Citalopram^b^ | Celexa^®^ | 10, 20, 40 mg tabs; 2 mg/ml solution | SSRI
Desvenlafaxine | Pristiq^®^ | 50, 100 mg tabs | SNRI
Duloxetine | Cymbalta^®^ | 20, 30, 60 mg caps | SSNRI
Escitalopram | Lexapro^®^ | 5, 10, 20 mg tabs 1 mg/ml solution | SSRI
Fluoxetine^b^ | Prozac^®^; Prozac Weekly^®^ | 10, 20, 40 mg caps; 4 mg/ml solution 90 mg caps | SSRI
Fluvoxamine^b^ | Luvox^®^ | 25, 50, 100 mg tabs | SSRI
Mirtazapine^c^ | Remer on^®^ Remer on Sol tab^®^ | 15, 30, 45 mg tabs; 15, 30, 45 mg orally Disintegrating tabs | SNRIc
Nefazodone^b^ | Serzone^®^d | 50, 100, 150, 200, 250 mg tabs | Other
Paroxetine^b^ | Paxil^®^; Paxil CR^®^ | 10, 20, 30, 40 mg tabs; 2 mg/ml solution; 12.5, 25, 37.5 mg CR tabs | SSRI
Sertraline^b^ | Zoloft^®^ | 25, 50, 100 mg tabs; 20 mg/ml solution | SSRI
Trazodone^b^ | Desyrel^®^ | 50, 100, 150, 300 mg tabs | Other
Venlafaxine^b^ | Effexor^®^; Effexor XR^®^ | 25, 37.5, 50, 75, 100 mg tabs; 37.5, 75, 150 mg XR caps | SNRI

caps = capsules; mg = milligram; ml = milliliter; SNRI = serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; tabs = tablets

a CR, SR, XL, and XR are registered trademarks referring to controlled, sustained, or extended-release dosage forms, respectively.

b Generic available for some dosage forms.

c Mirtazapine's mechanism of action is not clearly an SNRI, but it was grouped in this class owing to similarities.

d Only generic nefazodone is available in the United States.In our recent CER, we conducted MTC meta-analysis to derive estimates of the comparative efficacy among all SGAs for the treatment of major depressive disorder. Our primary efficacy outcome was the rate of response on the Hamilton Depression rating scale (HAM-D), defined as a 50 percent or greater improvement of scores from baseline. Figure 2 shows the evidence network that contributed data to the analysis.

Figure 2 Evidence network for mixed treatment comparison meta-analysis of second-generation antidepressants for achieving response for adults with depression

The figure shows the second-generation antidepressants and placebo used in the mixed treatment comparison analysis of response in adults with depression and the number of trials that contributed to each comparison. The drugs are as follows: fluoxetine, sertraline, fluvoxamine, duloxetine, bupropion, trazodone, venlafaxine, desvenlafaxine, citalopram, nefazodone, mirtazapine, paroxetine, escitalopram. There is also a placebo. Straight lines connect the drugs / placebo to each other. Three trials compared fluoxetine with sertraline. One trial compared fluoxetine with duloxetine. Six trials compared fluoxetine with placebo. One trial compared fluoxetine with nefazodone. Eight trials compared fluoxetine with venlafaxine. Five trials compared fluoxetine with paroxetine. One trial compared fluoxetine with mirtazapine. Two trials compared fluoxetine with bupropion. Three trials compared sertraline with bupropion. One trial compared sertraline with trazodone. Seven trials compared sertraline with placebo. One trial compared sertraline with paroxetine. Three trials compared sertraline with venlafaxine. One trial compared sertraline with nefazodone. One trial compared fluvoxamine with placebo. One trial compared fluvoxamine with citalopram. One trial compared bupropion with trazodone. Three trials compared bupropion with placebo. One trial compared trazodone with mirtazapine. One trial compared trazodone with paroxetine. One trial compared mirtazapine with paroxetine. Four trials compared paroxetine with placebo. Three trials compared paroxetine with duloxetine. One trial compared paroxetine with nefazodone. One trial compared paroxetine with escitalopram. Three trials compared venlafaxine with placebo. One trial compared venlafaxine with escitalopram. One trial compared escitalopram with fluoxetine. One trial compared escitalopram with placebo. Three trials compared escitalopram with duloxetine. One trial compared escitalopram with citalopram. One trial compared duloxetine with desvenlafaxine. Five trials compared desvenlafaxine with placebo. Eight trials compared duloxetine with placebo. Two trials compared nefazodone with placebo.

Our MTC meta-analysis found that SGAs had similar efficacy. There were some differences (based on the 95% credible intervals) for some pairwise comparisons that are likely not clinically relevant.

## Biologic Disease-Modifying Antirheumatic Drugs for Rheumatoid Arthritis

Our report on treatments for RA compared the benefits and harms of corticosteroids and oral and biologic disease-modifying antirheumatic drugs (DMARDs) for adults with RA.20 Nine biologic DMARDs were included in the CER (Table 2).

Table 2 Biologic DMARD treatments for rheumatoid arthritis

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | Injectable Supply | Usual Adult Dose
Abatacept | Bristol Myers Squibb Orencia^®^ | 250 mg powder in single-use vial, 125 mg/ml solution in a prefilled syringe | IV—Dosed according to body weight (< 60 kg = 500 mg; 60-100 kg = 750 mg; > 100 kg = 1,000 mg); dose repeated at 2 weeks and 4 weeks after initial dose, and every 4 weeks thereafter SQ—After a single IV infusion as a loading dose (as per body weight categories above), 125 mg should be given within a day, followed by 125 mg once a week
Adalimumab | Abbott Humira^®^ | 40 mg/0.8 ml prefilled pen or syringe, 20 mg/0.4 ml prefilled syringe | SQ—40 mg every other week; may increase to 40 mg every week in patients not taking concomitant MTX
Anakinra | Amgen Kineret^®^ | 100 mg/0.67 ml syringe | SQ—100 mg/day; dose should be decreased to 100 mg every other day in renal insufficiency or end-stage renal disease
Certolizumab Pegol | UCB Cimzia^®^ | 200 mg powder for reconstitution, 200 mg/ml solution in a pre-filled syringe | SQ—Initial dose of 400 mg, repeat dose 2 and 4 weeks after initial dose, followed by 200 mg every other week; for maintenance dosing, consider 400 mg every 4 weeks
Etanercept | Amgen Pfizer Immunex Enbrel^®^ | 50 mg/ml autoinjector or prefilled syringe, or as two 25 mg/0.5 mL single-use prefilled syringes or free-hand vials | SQ— 50 mg once weekly with or without MTX
Golimumab | Centocor Ortho Biotech Janssen Biotech, Inc. Simponi^®^ | 50 mg/0.5 ml prefilled syringe or autoinjector | SQ—50 mg once a month, in combination with MTX
Infliximab | Centocor Ortho Biotech Remicade^®^ | 100 mg lyophilized in a 20 ml vial | IV—3 mg/kg in combination with MTX at 0, 2, and 6 weeks followed by maintenance every 8 weeks thereafter; may increase to maximum of 10 mg/kg or treat as often as every 4 weeks
Rituximab | Biogen Idec/Genentech Rituxan^®^ | 100 mg/10 ml and 500 mg/50 ml vial | IV—In combination with MTX, two 1,000 mg IV infusions separated by 2 weeks (one course) every 24 weeks or based on clinical evaluation, but not sooner than every 16 weeks
Tocilizumab | Genentech/Roche Actemra^®^, RoActemra^®^ | 80 mg/4 ml, 200 mg/10 ml, 400 mg/20 ml vial | IV—4 mg/kg followed by an increase to 8 mg/kg based on clinical response; given every 4 weeks with or without MTX

IV = intravenous; kg = kilogram; mg = milligram; ml = milliliter; MTX = methotrexate; SQ = subcutaneous

* Listed trade names are limited to commonly prescribed U.S. products when multiple trade names are available.To compare the effectiveness of biologic DMARDs with each other, we conducted MTC meta-analyses of trials enrolling methotrexate-resistant patients with active RA. The primary efficacy outcome of our MTC meta-analysis was the American College of Rheumatology 50 percent response (ACR 50). We also conducted analyses using ACR 20 and ACR 70. Figure 3 shows the evidence network that contributed data to the analysis. The majority of evidence was from placebo-controlled trials; only one trial included a direct head-to-head comparison. Due to heterogeneity in study design of the included studies for certolizumab, it was excluded from the MTC meta-analysis. More information can be found in the full report.20

Figure 3 Evidence network for mixed treatment comparison meta-analysis of biologic DMARDs for achieving ACR 50 for adults with rheumatoid arthritis

Note: The total number of trials does not appear to equal 30 (the total number of studies included in the analysis) because some trials have multiple arms that were included.

The figure shows the biologic DMARDs and placebo used in the full network analysis of ACR50 response and the number of trials that contributed to each comparison. The drugs are as follows: abatacept, infliximab, golimumab, adalimumab, tocilizumab, rituximab, etanercept, and anakinra. There is also a placebo. Straight lines connect the drugs / placebo to each other. One trial compared abatacept with infliximab. Three trials compared abatacept with placebo. Six trials compared infliximab with placebo. Two trials compared golimumab with placebo. Seven trials compared adalimumab with placebo. Four trials compared tocilizumab with placebo. Two trials compared rituximab with placebo. Four trials compared etanercept with placebo. Three trials compared anakinra with placebo.

Our MTC meta-analyses found higher odds of achieving ACR 50 response for etanercept compared with most other biologic DMARDs (abatacept, adalimumab, anakinra, infliximab, rituximab, tocilizumab) for methotrexate-resistant patients with active RA. The ACR 50 odds ratio range for etanercept compared with most other biologic DMARDs was 2.4 to 5.2. The differences were potentially important (based on 95% credible intervals) for etanercept compared with abatacept, adalimumab, anakinra, infliximab, rituximab, or tocilizumab, but were not when compared with golimumab. Anakinra had the lowest mean response, and point estimates favored other biologic DMARDs over anakinra, but the differences were only potentially important (based on 95% credible intervals) when compared with adalimumab and etanercept for ACR 50.

## Scope and Key Questions

The main objectives of this report are to contribute to the body of literature on MTC meta-analysis by examining (1a) how results of Bayesian MTC methods compare with several frequentist indirect methods for various types of outcome measures, (1b) how Bayesian MTC methods perform for different types of evidence network patterns, (2) how study-level covariates can be incorporated with Bayesian MTC meta-analysis to explore heterogeneity through meta-regression, and (3) how findings of Bayesian MTC meta-analysis compare for different numbers of studies and different network pattern assumptions. For objectives 1 and 2, we aimed to conduct case studies using data from two recent CERs. For objective 3, we aimed to use simulated data. We address the KQs listed below.

KQ 1. How do the results of Bayesian MTC meta-analysis methods compare with those of several frequentist indirect methods? Related questions of interest included the following: For each of the common evidence network patterns, how do the Bayesian MTC methods compare with frequentist indirect methods? How do Bayesian MTC methods perform (e.g., precision, convergence) for different types of evidence network patterns?

KQ 2. How can meta-regression be used with Bayesian MTC meta-analysis to explore sources of heterogeneity?

KQ 3. How do findings of Bayesian MTC meta-analysis compare for different numbers of studies and network pattern assumptions?

For KQ 1, our choice of frequentist analytic methods to compare with the Bayesian MTC approach was based on our judgment regarding the methods most commonly considered by analysts conducting CERs. In addition, we selected frequentist methods with some evidence to support their validity. These included frequentist meta-regression, the Bucher method, and frequentist logistic regression. Of note, the frequentist methods used are not the analogue of the Bayesian methods implemented. We did not compare findings with the frequentist network meta-analysis method (i.e., the Lumley method).23 Our experience indicates that it is much more rarely used than the other methods, and comparisons between Bayesian MTC methods and frequentist network meta-analysis were not our intention.

We applied Bayesian MTC methods to a variety of different evidence networks using data from recent systematic reviews (of SGAs and biologic DMARDs) and using simulated data. For the first two KQs, we used the real-world bodies of literature described above (for SGAs and biologic DMARDs). For KQ 3, we use simulated data sets.

For KQ 2, we focused on clinically important issues to guide the meta-regressions. For the SGAs literature, some have questioned whether the medications are equally or less effective in older adults.24-27 To address this question, we conducted meta-regression by assessing whether efficacy differed in trials that enrolled older adults compared with trials that enrolled adults of any age. For biologic DMARDs, some have questioned whether treatment efficacy varies by disease duration of RA.28-30 To address this question, we conducted meta-regression using mean disease duration of subjects enrolled in each study as a continuous covariate.