# Future Research

We identified several issues that future research could address (Table 21). Many of these issues are related to further exploring the findings and limitations mentioned above.

Table 21 Possible targets for future research, by Key Question (KQ)

KQ | Potential Future Research
1 | Our findings were based on just two real-world datasets. To determine how well our findings hold up for various real-world situations, it will be important to conduct similar analyses for other existing networks. Many (perhaps 50) publications have used Bayesian MTC meta-analyses; those could be explored.
1 | For all of our Bayesian MTC meta-analyses, we ran a certain number of simulations (20,000) that were discarded and then used an additional 100,000 simulations in estimating the posterior probabilities. The impact of varying the number of simulations on the resulting findings is uncertain. Future research could address this impact to inform the most appropriate number of simulations.
1 | There were numerous options of various network patterns we could have selected. Future research could use an approach similar to cumulative meta-analysis and explore how the evidence evolved over time thus, choosing network patterns based on the chronology of study publication.
1 | Our analyses compared the results of various analytic approaches for both continuous and dichotomous outcomes, but we did not explore competing risk outcomes.47 Future research could include competing risk outcomes.
2 | We found a trend toward lack of efficacy or less efficacy for all of the SGAs in older adults. However, this finding could possibly be due to case mix, as studies of older adults may enroll subjects with less severe depression at baseline. Future analyses could explore this.
2 | We found a trend toward greater efficacy for those with greater mean disease duration. However, this finding could possibly be due to case mix, or other factors that we did not consider. Future analyses could explore this further.
2 | For our meta-regression models exploring (1) subgroup effects with a binary covariate and (2) interaction effects with a continuous covariate, we used models with the same interaction effect for all treatments. Other models have been described with independent, treatment-specific interactions and exchangeable, related treatment-specific interactions.5 Future research could explore whether these other models would significantly alter findings.
3 | For our simulations, we assumed a sample size of 100 subjects per study. Findings might differ if one investigated network patterns with larger or smaller (or varying) sample sizes.
3 | For our simulations, we assumed that each network had an equal number of studies available for each comparison of interest. Findings might differ if one investigated network patterns with varying numbers of studies for different comparisons.
3 | For our simulations, we used four network patterns (star, loop, one closed loop, and ladder). Many additional variations of these patterns could be assessed to determine if findings differ. In addition, complex networks that resemble real-world datasets could be developed to attempt to validate Bayesian MTC methods for specific treatments.^a^
3 | Our results raised some concerns about the validity of the Bayesian MTC method for one closed loop networks, and possibly for loop patterns (but less concern). Future simulations could include additional variation of the underlying data and complexity of network patterns to determine whether these findings are consistent.
3 | Our findings for one closed loop networks raise questions about the impact of a single “dangling” treatment on the results. Future simulation studies could explore this further to determine whether such “dangling” treatments should or should not be routinely included in Bayesian MTC meta-analyses. For our superior efficacy scenario, the more efficacious drug was the “dangling” treatment and future simulations could explore whether its position in the network would alter the findings.
3 | For our simulations, we chose to output the probability that each drug was the best. Future research could explore whether using different outputs (e.g. mean treatment response) would either alter conclusions or uncover additional findings.

SGAs = second-generation antidepressants

a For example, we could develop a simulated dataset that resemble the second-generation antidepressants or the biologic DMARDs real-world data—including setting the pre-determined truth to match our real-world findings and setting the number and sample sizes of included studies to match the real-world data. Then, we could run thousands of simulations to determine the validity of Bayesian MTC methods for a simulation that very closely matches a real-world dataset for a particular treatment and health condition.