# Peer Reviewers

Brad Carlin, Ph.D.

University of Minnesota

Minneapolis, MN

Andrea Cipriani, Ph.D.

University of Verona

Verona, Italy

Christopher Schmid, Ph.D.

Tufts Evidence-based Practice Center

Boston, MA

Fujian Song, Ph.D.

University of East Anglia

Norwich, UK