# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: We thank RTI International colleague Loraine Monroe for technical word processing.