# Discussion

## Main Findings by Key Question (KQ)

In this report, we addressed three KQs using real-world bodies of trial literature (for KQs 1 and 2) from recent comparative effectiveness reviews (CERs) of second-generation antidepressants (SGAs) and treatments for rheumatoid arthritis (RA) and using simulated data (for KQ 3). Below, we summarize the main findings by KQ. We then address the implications, limitations, research gaps, and conclusions.

### KQ 1 Bayesian Mixed Treatment Comparison (MTC) Methods Compared With Several Frequentist Indirect Methods, and Performance for Different Types of Evidence Network Patterns

We compared the results of the Bayesian MTC approach with results of several frequentist analytic methods—specifically, frequentist meta-regression, the Bucher method (adjusted indirect comparisons), and frequentist logistic regression. Of note, the frequentist methods used are not the analogues of the Bayesian methods implemented; i.e., we did not compare findings with a frequentist approach to MTC. Our choice of methods to compare, and our manner of conducting the analyses, was based on our judgment regarding the methods most commonly used by analysts conducting CERs. Our results for these comparisons, such as those related to precision, are not necessarily generalizable to other datasets (e.g., comparative effectiveness of other medication classes).

We found one of the main differences between Bayesian MTC meta-analysis and the typically-applied approach for frequentist meta-regression and the Bucher method to be that the Bayesian MTC approach was able to calculate a result for all drug-drug comparisons of interest whereas the other methods were unable to produce a result for many comparisons of interest. This was not surprising; it is because Bayesian MTC meta-analysis is able to produce a result for all comparisons in a connected network, whereas we only calculated results for these other frequentist indirect methods when there was a common comparator. Our results showed that some frequentist methods were unable to compute results for substantial proportions of the drug-drug comparisons of interest for some of the datasets. Despite that, our results may actually underestimate the proportion that one might determine for inability to calculate a result if running these analyses for a real-world CER because some guidance for certain methods would suggest not even attempting some of the analyses without a certain minimum number of studies. For example, we conducted meta-regression for all comparisons with a direct common comparator for which the statistical program was able to calculate a result; however, some research indicates that a certain minimal number of studies is needed for the meta-regression to produce a reliable result.33, 45 In other words, although technically we could produce results for meta-regression and the Bucher method for all of the comparisons for which we reported results, many of those, perhaps, should not be calculated if conducting a CER for the purpose of informing decisionmaking.

We were able to calculate results for all methods (Bayesian MTC and the three frequentist methods) for the RA dataset, but not for the SGA dataset. This is not surprising given the geometry of the two networks. The RA network is largely a star pattern with all treatments connected via placebo and with only one head-to-head study. The data is thus set up to allow any of the methods to determine results for each drug-drug comparison of interest (because of the common placebo comparator for each drug-drug comparison of interest). The SGA network, however, is a much more complex network. In this complex network, there were often too few studies with a common comparator to allow some frequentist methods to calculate results for many comparisons of interest.

Regarding various network patterns, the frequentist meta-regression and the Bucher method (in the manner we applied them) were least likely to be able to compute results for comparisons of interest for ladder patterns and most likely to be able to compute results for star patterns. The geometry of ladder patterns, by definition, does not include common comparators for most comparisons of interest, as each treatment will be linked to two other treatments at most.

In the cases of comparisons for which we were able to produce results, the majority of these results were in general agreement (i.e., they all found no statistically significant difference [for frequentist analyses] or no important difference [for Bayesian analyses] or they found a significant or important difference favoring the same drug). However, for each of the full networks, and for each outcome of interest, there were instances when some of the frequentist methods produced results that did not agree with those of the Bayesian MTC analysis. In each case, we do not know for certain which of the results represents the truth; instead, we just know that the findings do not agree. One might presume that the Bayesian MTC analysis is more likely to approximate the truth because it is able to incorporate more information from the full dataset; however, this assumption has not been proven. Validating such a conclusion would require a large number of real-world examples or data simulations using numerous situations and assumptions.

When considering precision, we speculated whether the Bayesian MTC method might generally produce more precise results because of its ability to incorporate all data (from both direct head-to-head trials and placebo-controlled trials). Our results did not find this to be the case. Across all the different network patterns (including the full networks), the logistic regression method produced the most precise result for a greater number of drug-drug comparisons than any of the other methods, followed by the Bayesian MTC method, and then the Bucher method. The meta-regression method fairly consistently produced the least precise result. The differences in precision between the various analyses were sometimes very small (on the order of hundredths), but were larger in some cases (e.g., on the order of 2 to 5 points different for an odds ratio), and very large in rare cases (e.g., a difference of 20 to 50).

For some specific networks (5 of the 16 networks or subcomponent networks that we analyzed), the Bayesian MTC results were the most precise. From our findings, we are unable to determine if any particular network geometry makes the Bayesian MTC method more or less likely to produce the most precise results. However, we should note that greater precision is only a good thing if the treatment effect estimated by the method is reflective of the truth (which is not something that we can confirm for these KQ 1 analyses as they are based on actual data rather than simulations).

### KQ 2 Meta-Regression With Bayesian MTC Meta-Analysis

For the first meta-regression, we hypothesized that differences in efficacy of SGAs may exist for older adults (≥55 years) than for younger adults. We explored this hypothesis through a subgroup meta-regression. We found a trend toward lack of efficacy or lesser efficacy for all of the SGAs in older adults. However, this finding could be due to case mix, as studies of older adults may enroll subjects with less severe depression at baseline.

For the second meta-regression, we hypothesized that treatment response may differ for patients with longer disease duration. We speculated that longer disease duration was related to more severe RA (and potentially more room for improvement). We explored this hypothesis through a continuous covariate meta-regression with mean disease duration as the continuous covariate. We focused on the response to etanercept to determine whether controlling for this covariate might alter findings because our MTC meta-analysis showed etanercept yielding a greater treatment response than most other biologic DMARDs. We found a trend toward greater efficacy for those with greater mean disease duration. In addition, we found that the superior relative efficacy of etanercept compared with other biologic DMARDs was reduced; furthermore, it was no longer significantly greater (based on the 95% credible intervals) than most of the other biologic DMARDs (with the exception of anakinra). However, reporting bias might underlie this finding because the only 2 trials (out of 31) that were not included in the analysis (because they did not report mean disease duration) compared etanercept and placebo.

### KQ 3 Stability of the Bayesian MTC Analyses for Different Numbers of Studies and Network Pattern Assumptions

Our simulations for KQ 3 revealed several important findings. We note that the differences hypothesized between drugs and placebo (for the equivalent efficacy scenario) and between drug 4 and drugs 1 through 3 (for the superior efficacy scenario) were relatively large, and our findings do not necessarily apply to other scenarios (e.g., smaller differences between treatments). First, the simulations validated the ability of the Bayesian MTC meta-analyses to produce results that would yield conclusions that reflect the truth for two scenarios—one with three medications of equivalent efficacy and a placebo arm and one with one medication of superior efficacy. The analyses were generally able to produce findings reflecting the underlying truth with only one study per comparison.

Second, for the equivalent efficacy scenario, results changed very little based on the number of studies available for each comparison. For the superior efficacy scenario, however, we found larger differences between scenarios with one available study for each comparison and scenarios with two studies for each comparison, and similar results with little variation between two and 10 studies per comparison.

Third, networks with a one closed loop pattern did not perform as expected and often produced results that might yield inaccurate conclusions. These networks produced results for the equivalent efficacy scenario that might lead investigators to conclude one of the drugs (drug four) to have the greatest likelihood of efficacy, regardless of the number of studies available for each comparison (i.e., the accuracy of results did not improve even with 10 studies per comparison). In contrast, for the superior efficacy scenario, the one closed loop found the correct drug to have the greatest likelihood of efficacy, but with much lower probability compared with the other network patterns (approximately 50% vs. well over 90%), regardless of the number of studies per comparison. We are uncertain as to why this occurred and it was an unexpected finding. Perhaps it could be related to the position of the superior drug within the network (it was the “dangling” treatment in our simulations, and thus the least connected with the rest of the network; see the following section). A drug could have three potentially different positions, even in our relatively simple one closed loop network. The superior drug could be the “dangling” treatment (as in our simulation), it could be connected to everything else (like drug 3 in the figure in the following section), or it could be connected to two of the other three drugs. Regardless, future research should attempt to explore this further and to reproduce the findings using different simulated data.

## Implications for Comparative Effectiveness Reviews

Investigators have a number of analytic strategies from which to choose when conducting indirect comparisons (Bayesian MTC meta-analysis, frequentist meta-regression, the Bucher method, logistic regression, and others). Our findings indicate that the choice of method can have an important impact on the results. Although the various methods we compared using our two real-world datasets found results that generally agreed for the majority of drug-drug comparisons, we also found some instances where results differed for the same comparison. Even though we do not know with certainty which method is correct from these real-world comparisons, our findings identified several advantages of the Bayesian MTC approach (Table 20).

Table 20 Advantages and disadvantages of the Bayesian MTC approach

Advantages | Disadvantages
Able to incorporate both direct evidence (from head-to-head trials) and indirect evidence (e.g., placebo-controlled trials) into a single analysis | Less accessible to many investigators because the analyses are usually run using software that is unfamiliar or less familiar to many of them (usually run using WinBUGS)
Able to produce results for all comparisons of interest within a connected network (even for ladder network patterns or complex networks that limit the ability of other methods to get any results for some comparisons of interest) | Requires greater statistical expertise than some other methods
Able to directly calculate the probability that each drug is the best treatment | Further research is needed to evaluate performance in specific scenarios^a^
Able to adjust for correlations within multi-arm trials | Might not produce accurate results for one closed loop networks
Able to incorporate meta-regression to assess heterogeneity (e.g., for subgroups or to control for covariates), all within one model | Possibly sensitive to the prior probabilities chosen (therefore recommended to generally use flat priors)46
Appears to produce valid, accurate results for star and ladder network patterns

a Such as those with various numbers of studies available per comparison, various sample sizes of studies, and complex network patterns.

Our simulations (KQ 3) supported the validity of the Bayesian MTC method for star and ladder network patterns. However, they raised some concerns about the validity of the Bayesian MTC method for one closed loop networks and possibly for loop patterns (albeit lesser concerns), as results did not converge on the pre-determined truth. These findings demonstrate the need for additional exploration of more hypothetical scenarios, and analysts should be cognizant of the fact that Bayesian MTC methods may not produce accurate results for one closed loop networks such as the one used in our simulation (Figure 12). We are uncertain as to why the results did not converge on the truth; we wonder whether a “dangling” treatment (where 1 treatment is peripheral to the rest of the network, like drug 4 in the figure) might reduce accuracy.

Figure 12 One closed loop network pattern used in simulation

The figure displays the one closed loop pattern used in the simulation study. It is a graphical representation, with boxes representing drugs, and lines connecting boxes that represent a drug-drug comparison present in the literature. Drug 1 connected by lines to drug 2 and drug 3; drug 2 is connected with a line to both drug 1 and drug 3; and drug 3 is connected by a line to both drug 1 and drug 2. In this way, each drug is connected in a circle. Another drug, drug 4, is connected with a line to drug 3. This drug 4 in the one closed loop pattern represents an offshoot of the circle created by drug 1, drug 2, and drug 3.

Surprisingly, our simulations did not find much difference between scenarios when one study was available for each comparison and those when more studies (2, 3, 5, or 10) were available. We initially expected that results from analyses with one study available for each comparison would be much less likely to approximate the underlying truth, but found that this was not the case. We previously wondered whether Bayesian MTC meta-analyses should not be attempted when there is only one study per comparison, hypothesizing that results would be much less accurate. However, this hypothesis was not supported by our simulations. It is possible that our choice of relatively large differences between drugs and placebo (for the equivalent efficacy scenario) and between drug 4 and drugs 1 through 3 (for the superior efficacy scenario) influenced this finding. In other words, if differences were smaller, analyses with one study available for each comparison could be less likely to approximate the underlying truth.

## Limitations

Our findings from KQs 1 and 2 are not necessarily generalizable to treatment networks for other medications or diseases. Some of the findings may be a consequence of the underlying body of evidence (e.g., the number of studies for each comparison, the variation of findings in studies making the same comparison) and all of its inherent biases (e.g., selective outcome reporting, publication bias) rather than the network pattern, per se.

In addition, our selection of various sub-component network patterns was based on maximizing the amount of data available for each sub-network. Due to limited time and resources, we could not evaluate every possible network pattern within each dataset. Other approaches to choosing network patterns could also have been informative (e.g., based on entry of drugs into the market, or chronologically by publication date). But, for the purposes of this report we felt that an approach based on maximizing the amount of data available was reasonable. Due to the nature of the sub-component network patterns (i.e., that they include only some of the available evidence from a body of literature), the findings for comparisons of sub-components of the full networks are for exploration of the various types of analyses only and should not be used to inform clinical decisions.

In KQ 1, we reported several measures to compare the findings of the Bayesian MTC method with various frequentist methods. The measures have some limitations. For example, regarding the number of comparisons for which each frequentist method was unable to produce a result, our results likely underestimate the numbers that some analysts might determine if running these analyses for a CER—because some guidance would suggest not even attempting some analyses without a certain minimum number of studies. For example, we conducted meta-regression for all comparisons that the statistical program was able to calculate a result, but it has been suggested that a certain minimal number of studies per covariate is needed for the meta-regression to produce a reliable result.33, 45 In other words, the gap would actually be larger between the Bayesian MTC and meta-regression for the number of comparisons the method was unable to produce a result.

Another measure we used was the percent agreement between results of the Bayesian MTC method and those of each frequentist method. We considered results to agree if both methods produced a non-statistically significant (for frequentist analyses) or an unimportant (for Bayesian analyses) result for the comparison or if both analyses found a statistically significant or important result favoring the same treatment. This is an oversimplification of how results would be interpreted in a CER. For example, we did not determine whether the ultimate conclusions about comparative effectiveness or the strength of evidence grades would agree.

Our choice of analytic methods to compare was based on our judgment regarding the methods most commonly considered by analysts conducting CERs. In addition, we selected frequentist methods with some evidence to support their validity. However, we did not compare findings with the frequentist network meta-analysis method (i.e., Lumley method).23 Our experience indicates that it is much more rarely used than the other methods, and it is generally felt that the Bayesian MTC approach has several advantages over frequentist network meta-analysis.

For Bayesian MTC analyses, we did not explore sensitivity analyses with various uninformative priors or with informative priors. However, we do not believe that the current state of the literature (i.e., the literature on SGAs and biologic DMARDs for RA) would support using informative priors. In addition, we did not include inconsistency models to test model assumptions.

For KQ 2, both of our meta-regressions rely on averages taken over patients in the trials. As such, ecological bias is a potential limitation.

Our simulations for KQ 3 were limited by the assumptions that we made to develop the scenarios. Our simulations did not examine many scenarios observed in real-world networks. For example, we set each scenario to include an equal number of studies for each drug-drug comparison, we set the sample size at 100 subjects for each study, and we did not include any multi-arm studies. In addition, we used a non-random network structure, and we did not simulate incoherence. Findings might differ if one investigated network patterns with varying numbers of studies for different comparisons or with larger or smaller (or varying) sample sizes, or if one incorporated additional complexity in the simulations.

For our simulations in KQ 3, we chose to output the probability that each drug was the best (i.e., most efficacious) for ease of presentation and to use an outcome recognizable to analysts familiar with Bayesian MTC. Being able to produce probability rankings is an advantage of the Bayesian MTC approach. However, one could argue that using mean treatment response would have been more appropriate, because it would have allowed outputs that were directly comparable with the underlying truths that we specified.

Finally, data were too sparse to include some analyses we had aimed to include at the outset. We wanted to run analyses for a continuous outcome from the RA dataset (mean change in Health Assessment Questionnaire score), as we had done for the SGA dataset, but too few studies reported sufficient data.