# Conclusions

Bayesian MTC methods allow investigators to calculate results for many more comparisons of interest for some network patterns, including ladders and complex networks, than frequentist meta-regression or the Bucher method, in the manner that they are typically applied. When Bayesian MTC methods and various frequentist methods are each able to calculate results (as typically applied), the findings are usually in general agreement. However, findings differ for a small proportion (less than 10%) of comparisons, which could lead to differences in conclusions.

Our simulations support the validity of Bayesian MTC methods for star and ladder network patterns, but raise some concerns about one closed loop network patterns, and possibly about loop patterns (but less concern). Simulations generally found similar results for scenarios when 1 study was available for each comparison and those when more studies (2, 3, 5, or 10) were available.

Further research is needed to explore additional real-world datasets and simulated data to determine if these findings are reproducible or generalizable and to better understand the accuracy and validity of Bayesian MTC methods for various scenarios. We hope this research will inform Evidence-based Practice Centers and others conducting CERs about Bayesian MTC methods and help to inform additional research and guidance for the use of these methods.