# Distribution Plots From Simulation Study

For each of the scenarios in KQ3, the histograms below provide a graphical representation of the distribution of the probability of best treatment statistic.

Figure F-1 Distribution of best treatment probability: Star pattern, equivalent efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the star pattern under the equivalent efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 16 of the report.

Figure F-2 Distribution of best treatment probability: Loop pattern, equivalent efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the loop pattern under the equivalent efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 16 of the report.

Figure F-3 Distribution of best treatment probability: One closed loop pattern, equivalent efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the one closed loop pattern under the equivalent efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 16 of the report.

Figure F-4 Distribution of best treatment probability: Ladder pattern, equivalent efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the ladder pattern under the equivalent efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 16 of the report.

Figure F-5 Distribution of best treatment probability: Star pattern, superior efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the star pattern under the superior efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 18 of the report.

Figure F-6 Distribution of best treatment probability: Loop pattern, superior efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the loop pattern under the superior efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 18 of the report.

Figure F-7 Distribution of best treatment probability: One closed loop pattern, superior efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the one closed loop pattern under the superior efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 18 of the report.

Figure F-8 Distribution of best treatment probability: Ladder pattern, superior efficacy scenario

The figure is a panel plot of histograms showing the distribution of the probability of best treatment statistic for the ladder pattern under the superior efficacy data scenario. The panel plot is comprised of 20 individual histogram plots, one for each scenario where the study sample size ranged from 1, 2, 3, 5, and 10, and for each drug 1, 2, 3, and 4. The x-axis for each plot is the distribution of the mean probability of best treatment, ranging from 0 to 1. The y-axis represents the frequency density of the rankings. The plots represent the data in Table 18 of the report.