# Comparison of Precision

For each set of results in Appendix D, the tables below provide a comparison of the precision (determined by width of the 95% credible interval or confidence interval) for the Bayesian MTC meta-analysis and the frequentist methods used. The darkest shading indicates the most precise result and the lightest indicates the least precise. The drug-drug comparisons for each of the tables below are limited to those where at least one of the frequentist methods could produce a result.

Table E-1 Comparison of response for second-generation antidepressants (full network), by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
BUP vs. CIT | 0.58 (0.29 to 1.39) | NA | NA | 0.81 (0.48 to 1.35)
BUP vs. DES | 0.88 (0.59 to 1.40) | 0.78 (0.30 to 2.01) | 0.77 (0.40 to 1.50) | 0.93 (0.70 to 1.23)
BUP vs. DUL | 0.99 (0.69 to 1.46) | 0.85 (0.50 to 1.45) | 0.87 (0.56 to 1.36) | 1.00 (0.78 to 1.29)
BUP vs. ESC | 0.73 (0.50 to 1.12) | 1.04 (0.21 to 5.11) | 1.04 (0.59 to 1.85) | 0.76 (0.58 to 1.00)
BUP vs. FLUO | 1.07 (0.78 to 1.52) | 0.98 (0.56 to 1.71) | 0.98 (0.62 to 1.56) | 1.05 (0.83 to 1.32)
BUP vs. FLUV | 0.62 (0.26 to 1.79) | 0.59 (0.02 to 15.8) | 0.58 (0.14 to 2.46) | 1.03 (0.54 to 1.94)
BUP vs. MIR | 0.75 (0.45 to 1.35) | 0.71 (0.0 to 113.5) | IS | 0.76 (0.51 to 1.12)
BUP vs. NEF | 0.90 (0.55 to 1.58) | 0.65 (0.19 to 2.18) | 0.82 (0.35 to 1.91) | 0.94 (0.64 to 1.39)
BUP vs. PAR | 0.92 (0.64 to 1.38) | 0.94 (0.45 to 1.99) | 0.71 (0.38 to 1.33) | 0.92 (0.70 to 1.19)
BUP vs. SER | 0.90 (0.67 to 1.26) | 0.80 (0.49 to 1.30) | 0.80 (0.52 to 1.24) | 0.91 (0.73 to 1.14)
BUP vs. TRA | 1.09 (0.67 to 1.93) | 0.54 (0.06 to 4.55) | IS | 1.01 (0.69 to 1.50)
BUP vs. VEN | 0.83 (0.58 to 1.22) | 0.74 (0.33 to 1.62) | 0.73 (0.42 to 1.28) | 0.83 (0.64 to 1.07)
CIT vs. DES | 1.32 (0.66 to 3.14) | NA | NA | 1.15 (0.69 to 1.91)
CIT vs. DUL | 1.48 (0.76 to 3.34) | NA | NA | 1.24 (0.77 to 2.01)
CIT vs. ESC | 1.11 (0.59 to 2.38) | NA | NA | 0.94 (0.59 to 1.49)
CIT vs. FLUO | 1.60 (0.82 to 3.63) | IS | IS | 1.30 (0.80 to 2.11)
CIT vs. FLUV | 1.03 (0.53 to 2.23) | NA | NA | 1.27 (0.75 to 2.14)
CIT vs. MIR | 1.11 (0.51 to 2.93) | NA | NA | 0.94 (0.53, to 1.67)
CIT vs. NEF | 1.34 (0.63 to 3.46) | NA | NA | 1.17 (0.66 to 2.07)
CIT vs. PAR | 1.38 (0.70 to 3.15) | NA | NA | 1.13 (0.69 to 1.85)
CIT vs. SER | 1.34 (0.69 to 3.08) | NA | NA | 1.13 (0.69 to 1.84)
CIT vs. TRA | 1.61 (0.74 to 4.35) | NA | NA | 1.26 (0.69 to 2.27)
CIT vs. VEN | 1.23 (0.62 to 2.84) | NA | NA | 1.03 (0.63 to 1.69)
DES vs. DUL | 1.10 (0.78 to 1.59) | 1.10 (0.59 to 2.03) | 1.14 (0.63 to 2.05) | 1.08 (0.87 to 1.34)
DES vs. ESC | 0.81 (0.55 to 1.24) | 1.35 (0.22 to 8.18) | 1.35 (0.67 to 2.71) | 0.82 (0.63 to 1.06)
DES vs. FLUO | 1.18 (0.84 to 1.73 | 1.27 (0.64 to 2.54) | 1.27 (0.69 to 2.34) | 1.13 (0.89 to 1.42)
DES vs. FLUV | 0.68 (0.29 to 1.99) | 0.76 (0.06 to 10.1) | 0.76 (0.17 to 3.37) | 1.10 (0.59 to 2.08)
DES vs. MIR | 0.82 (0.48 to 1.54) | NA | NA | 0.82 (0.55 to 1.20)
DES vs. NEF | 1.00 (0.61 to 1.75) | 0.83 (0.21 to 3.27) | 1.07 (0.42 to 2.71) | 1.02 (0.70 to 1.48)
DES vs. PAR | 1.02 (0.70 to 1.53) | 1.23 (0.51 to 2.96) | 0.93 (0.44 to 1.94) | 0.99 (0.77 to 1.27)
DES vs. SER | 1.00 (0.71 to 1.46) | 1.05 (0.57 to 1.93) | 1.04 (0.58 to 1.87) | 0.98 (0.78 to 1.24)
DES vs. TRA | 1.20 (0.69 to 2.26) | NA | NA | 1.09 (0.72 to 1.65)
DES vs. VEN | 0.91 (0.63 to 1.38) | 0.95 (0.36 to 2.54) | 0.96 (0.48 to 1.89) | 0.89 (0.69 to 1.15)
DUL vs. ESC | 0.74 (0.56 to 0.99) | 1.23 (0.54 to 2.82) | 1.19 (0.73 to 1.94) | 0.76 (0.63 to 0.91)
DUL vs. FLUO | 1.07 (0.82 to 1.43) | 1.12 (0.75 to 1.68) | 1.12 (0.79 to 1.59) | 1.05 (0.87 to 1.26)
DUL vs. FLUV | 0.62 (0.27 to 1.72) | 0.69 (0.11 to 4.35) | 0.67 (0.16 to 2.72) | 1.02 (0.55 to 1.89)
DUL vs. MIR | 0.74 (0.45 to 1.30) | 0.74 (0.20 to 2.69) | IS | 0.76 (0.53 to 1.08)
DUL vs. NEF | 0.90 (0.58 to 1.51) | 0.77 (0.33 to 1.79) | 0.94 (0.43 to 2.07) | 0.94 (0.66 to 1.35)
DUL vs. PAR | 0.93 (0.70 to 1.24) | 1.08 (0.66 to 1.77) | 0.82 (0.47 to 1.41) | 0.92 (0.76 to 1.10)
DUL vs. SER | 0.90 (0.68 to 1.22) | 0.92 (0.64 to 1.31) | 0.92 (0.67 to 1.25) | 0.91 (0.75 to 1.11)
DUL vs. TRA | 1.08 (0.65 to 1.93) | 1.25 (0.07 to 21.4) | IS | 1.01 (0.69 to 1.49)
DUL vs. VEN | 0.82 (0.61 to 1.15) | 0.92 (0.54 to 1.59) | 0.84 (0.53 to 1.34) | 0.83 (0.67 to 1.03)
ESC vs. FLUO | 1.44 (1.06 to 1.99) | 0.94 (0.42 to 2.11) | 0.94 (0.57 to 1.57) | 1.38 (1.12 to 1.70)
ESC vs. FLUV | 0.83 (0.37 to 2.26) | IS | 0.56 (0.13 to 2.40) | 1.35 (0.74 to 2.47)
ESC vs. MIR | 1.00 (0.60 to 1.80) | IS | IS | 1.00 (0.69 to 1.44)
ESC vs. NEF | 1.21 (0.75 to 2.07) | IS | 0.79 (0.33 to 1.88) | 1.24 (0.86 to 1.80)
ESC vs. PAR | 1.24 (0.90 to 1.74) | 0.69 (0.15 to 3.13) | 1.15 (0.71 to 1.88) | 1.21 (0.98 to 1.49)
ESC vs. SER | 1.21 (0.88 to 1.70) | 0.77 (0.39 to 1.52) | 0.77 (0.47 to 1.24) | 1.20 (0.97 to 1.49)
ESC vs. TRA | 1.45 (0.85 to 2.68) | IS | IS | 1.33 (0.90 to 1.99)
ESC vs. VEN | 1.11 (0.80 to 1.58) | 0.71 (0.14 to 3.46) | 0.71 (0.39 to 1.28) | 1.09 (0.87 to 1.37)
FLUO vs. FLUV | 0.57 (0.25 to 1.60) | 0.60 (0.09 to 4.02) | 0.60 (0.15 to 2.44) | 0.98 (0.53 to 1.81)
FLUO vs. MIR | 0.69 (0.43 to 1.17) | 0.77 (0.34 to 1.71) | IS | 0.72 (0.51 to 1.02)
FLUO vs. NEF | 0.84 (0.55 to 1.36) | 0.66 (0.28 to 1.56) | 0.84 (0.38 to 1.86) | 0.90 (0.64 to 1.21)
FLUO vs. PAR | 0.86 (0.66 to 1.13) | 0.73 (0.39 to 1.37) | 0.73 (0.41 to 1.28) | 0.88 (0.72 to 1.06)
FLUO vs. SER | 0.84 (0.66 to 1.06) | 0.82 (0.54 to 1.23) | 0.82 (0.58 to 1.15) | 0.87 (0.74 to 1.03)
FLUO vs. TRA | 1.00 (0.62 to 1.75) | 1.30 (0.22 to 7.66) | IS | 0.97 (0.66 to 1.41)
FLUO vs. VEN | 0.77 (0.61 to 0.97) | 0.75 (0.42 to 1.35) | 0.75 (0.46 to 1.22) | 0.79 (0.67 to 0.94)
FLUV vs. MIR | 0.97 (0.40 to 3.17) | NA | NA | 0.74 (0.37 to 1.47)
FLUV vs. NEF | 1.18 (0.50 to 3.72) | IS | 1.40 (0.29 to 6.80) | 0.92 (0.46 to 1.83)
FLUV vs. PAR | 1.21 (0.54 to 3.5) | 1.61 (0.13 to 20.0) | IS | 0.89 (0.48 to 1.66)
FLUV vs. SER | 1.18 (0.52 to 3.38) | 1.37 (0.23 to 8.11) | IS | 0.89 (0.48 to 1.65)
FLUV vs. TRA | 1.42 (0.57 to 4.70) | NA | NA | 0.99 (0.49 to 1.99)
FLUV vs. VEN | 1.08 (0.48 to 3.12) | 1.26 (0.05 to 35.0) | 1.26 (0.30 to 5.32) | 0.81 (0.43 to 1.51)
MIR vs. NEF | 1.14 (0.63 to 2.29) | IS | IS | 1.25 (0.78 to 1.99)
MIR vs. PAR | 1.18 (0.74 to 1.97) | 1.25 (0.43 to 3.64) | IS | 1.21 (0.86 to 1.70)
MIR vs. SER | 1.14 (0.71 to 1.98) | 0.89 (0.17 to 4.61) | IS | 1.20 (0.84 to 1.72)
MIR vs. TRA | 1.40 (0.84 to 2.54) | IS | IS | 1.34 (0.89 to 2.01)
MIR vs. VEN | 1.04 (0.64 to 1.85) | 1.03 (0.33 to 3.20) | IS | 1.10 (0.76 to 1.58)
NEF vs. PAR | 0.98 (0.62 to 1.63) | 1.46 (0.47 to 4.51) | 0.87 (0.35 to 2.15) | 0.97 (0.68 to 1.40)
NEF vs. SER | 0.96 (0.63 to 1.54) | 1.23 (0.56 to 2.67) | 0.98 (0.44 to 2.14) | 0.97 (0.69 to 1.36)
NEF vs. TRA | 1.15 (0.63 to 2.34) | IS | IS | 1.07 (0.66 to 1.74)
NEF vs. VEN | 0.87 (0.55 to 1.45) | 0.84 (0.29 to 2.41) | 0.90 (0.38 to 2.11) | 0.88 (0.61 to 1.26)
PAR vs. SER | 0.96 (0.72 to 1.31) | 1.14 (0.71 to 1.84) | 1.12 (0.65 to 1.93) | 0.99 (0.81 to 1.22)
PAR vs. TRA | 1.16 (0.71 to 2.04) | IS | IS | 1.11 (0.76 to 1.62)
PAR vs. VEN | 0.88 (0.65 to 1.23) | 0.78 (0.36 to 1.70) | 1.03 (0.54 to 1.96) | 0.91 (0.72 to 1.14)
SER vs. TRA | 1.19 (0.74 to 2.06) | 1.03 (0.13 to 8.31) | IS | 1.11 (0.76 to 1.62)
SER vs. VEN | 0.91 (0.70 to 1.21) | 0.92 (0.55 to 1.54) | 0.92 (0.58 to 1.45) | 0.91 (0.75 to 1.11)
TRA vs. VEN | 0.71 (0.43 to 1.30) | 1.51 (0.23 to 9.95) | IS | 0.82 (0.55 to 1.21)

Abbreviations: BUP = bupropion; CIT = citalopram; DES = desvenlafaxine; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; MIR = mirtazapine; NA = not applicable; NEF = nefazodone; PAR = paroxetine; SER = sertraline; TRA = trazodone; VEN = velafaxine

Table E-2 Comparison of mean change in HAM-D for second-generation antidepressants (full network), by method of analysis: Weighted mean difference (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method
BUP vs. ESC | 1.42 (-1.50 to 4.43) | IS | 0.00 (-2.79 to 2.79)
BUP vs. FLUV | 2.24 (-0.96 to 5.47) | IS | 0.55 (-2.47 to 3.57)
BUP vs. TRA | 1.44 (-1.70 to 4.68) | IS | 0.60 (-3.01 to 4.21)
BUP vs. VEN | 1.62 (-1.30 to 4.52) | IS | -0.74 (-4.21 to 2.73)
CIT vs. DUL | 0.12 (-2.90 to 3.09) | -0.95 (-32.88 to 30.98) | 0.85 (-2.49 to 4.19)
CIT vs. FLUO | 0.01 (-3.10 to 3.03) | IS | -0.20 (-2.88 to 2.48)
CIT vs. SER | 0.27 (-2.80 to 3.30) | IS | 0.10 (-2.76 to 2.96)
CIT vs. VEN | 1.09 (-2.00 to 4.14) | IS | -1.10 (-4.30 to 2.10)
DES vs. DUL | -0.48 (-2.40 to 1.40) | -0.65 (-2.92 to 1.61) | -0.68 (-2.25 to 0.90)
DES vs. ESC | 0.29 (-1.70 to 2.32) | -1.23 (-5.06 to 2.61) | -1.23 (-2.97 to 0.51)
DES vs. FLUO | -0.59 (-2.60 to 1.28) | 0.72 (-4.27 to 5.71) | -0.27 (-5.19 to 4.64)
DES vs. PAR | -0.58 (-2.40 to 1.31) | -0.67 (-3.33 to 2.00) | -0.72 (-2.65 to 1.21)
DES vs. SER | -0.33 (-2.20 to 1.53) | -0.41 (-2.68 to 1.86) | -0.47 (-2.15 to 1.21)
DES vs. VEN | 0.49 (-1.50 to 2.43) | 1.92 (-3.05 to 6.89) | 1.92 (-0.34 to 4.18)
DUL vs. ESC | 0.77 (-0.49 to 2.10) | -0.55 (-4.68 to 3.58) | -0.55 (-2.34 to 1.24)
DUL vs. FLUO | -0.11 (-1.50 to 1.19) | 1.15 (-3.45 to 5.76) | 0.41 (-4.53 to 5.34)
DUL vs. FLUV | 1.59 (-0.42 to 3.64) | 1.27 (-5.47 to 8.00) | 1.40 (-0.43 to 3.22)
DUL vs. MIR | 1.83 (-0.77 to 4.50) | 2.23 (-8.66 to 13.12) | -2.23 (-3.91 to -0.55)
DUL vs. PAR | -0.10 (-1.30 to 1.17) | -0.04 (-2.59 to 2.51) | -0.04 (-2.02 to 1.94)
DUL vs. SER | 0.15 (-1.30 to 1.53) | 0.20 (-2.00 to 2.39) | 0.21 (-1.53 to 1.95)
DUL vs. TRA | 0.80 (-1.20 to 2.79) | -0.10 (-13.31 to 13.11) | -0.70 (-2.74 to 1.34)
DUL vs. VEN | 0.97 (-0.48 to 2.41) | 2.60 (-2.15 to 7.35) | 2.60 (0.29 to 4.91)
ESC vs. FLUO | -0.88 (-2.40 to 0.48) | 0.91 (-49.15 to 50.98) | 0.96 (-4.03 to 5.95)
ESC vs. FLUV | 0.82 (-1.30 to 2.93) | IS | 0.55 (-2.59 to 3.69)
ESC vs. NEF | -1.70 (-5.00 to 1.47) | IS | -1.90 (-4.77 to 0.97)
ESC vs. PAR | -0.87 (-2.30 to 0.54) | 0.26 (-5.51 to 6.03) | 0.51 (-1.60 to 2.62)
ESC vs. SER | -0.63 (-2.10 to 0.78) | 0.77 (-3.44 to 4.97) | 0.76 (-1.13 to 2.65)
ESC vs. TRA | 0.02 (-2.00 to 2.05) | 0.78 (-17.89 to 19.45) | -2.99 (-5.85 to -0.13)
ESC vs. VEN | 0.20 (-1.30 to 1.63) | IS | 3.15 (0.73 to 5.57)
FLUO vs. MIR | 1.94 (-0.53 to 4.61) | 1.72 (-4.68 to 8.11) | -2.12 (-4.30 to 0.06)
FLUO vs. PAR | 0.01 (-1.00 to 1.22) | -1.08 (-7.51 to 5.36) | -0.45 (-5.51 to 4.61)
FLUO vs. SER | 0.26 (-1.00 to 1.65) | -0.92 (-5.82 to 3.97) | -0.20 (-5.17 to 4.77)
FLUO vs. VEN | 1.08 (-0.14 to 2.41) | 2.24 (-48.69 to 53.16) | 2.19 (-3.00 to 7.39)
FLUV vs. TRA | -0.80 (-3.20 to 1.59) | IS | -2.10 (-4.56 to 0.37)
FLUV vs. VEN | -0.62 (-2.60 to 1.35) | 3.53 (-20.92 to 27.98) | -1.21 (-3.33 to 0.92)
MIR vs. TRA | -1.00 (-3.90 to 1.84) | IS | 1.53 (-0.83 to 3.89)
MIR vs. VEN | -0.86 (-3.50 to 1.71) | IS | 2.42 (0.42 to 4.42)
NEF vs. PAR | 0.80 (-2.20 to 3.96) | 2.01 (-20.25 to 24.27) | 0.61 (-2.14 to 3.36)
NEF vs. TRA | 1.70 (-1.60 to 5.15) | 2.68 (-17.72 to 23.08) | -1.09 (-4.23 to 2.05)
NEF vs. VEN | 1.87 (-1.20 to 5.04) | IS | 2.50 (-0.64 to 5.64)
PAR vs. SER | 0.24 (-1.10 to 1.47) | 0.24 (-2.46 to 2.93) | 0.25 (-1.82 to 2.32)
PAR vs. TRA | 0.89 (-0.84 to 2.61) | 0.67 (-6.88 to 8.22) | -1.70 (-4.45 to 1.05)
PAR vs. VEN | 1.07 (-0.17 to 2.24) | 2.66 (-4.47 to 9.79) | 2.64 (0.08 to 5.20)
SER vs. VEN | 0.82 (-0.44 to 2.09) | 2.38 (-2.49 to 7.26) | 2.39 (0.01 to 4.77)
TRA vs. VEN | 0.18 (-1.80 to 2.08) | 0.79 (-5.72 to 7.29) | -0.85 (-4.00 to 2.31)

Abbreviations: BUP = bupropion; CIT = citalopram; DES = desvenlafaxine; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; MIR = mirtazapine; NA = not applicable; NEF = nefazodone; PAR = paroxetine; SER = sertraline; TRA = trazodone; VEN = velafaxine

Table E-3 Comparison of ACR50 response for biologic DMARDs (full network), by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. ADA | 0.65 (0.37 to 1.20) | 0.67 (0.34 to 1.33) | 0.64 (0.38 to 1.08) | 0.83 (0.60 to 1.14)
ABA vs. ANA | 1.26 (0.63 to 2.78) | 1.32 (0.63 to 2.79) | 1.32 (0.78 to 2.24) | 1.82 (1.20 to 2.76)
ABA vs. ETA | 0.19 (0.08 to 0.50) | 0.21 (0.08 to 0.57) | 0.21 (0.10 to 0.45) | 0.41 (0.26 to 0.66)
ABA vs. GOL | 0.54 (0.23 to 1.49) | 0.59 (0.18 to 1.89) | 0.57 (0.28 to 1.17) | 0.76 (0.43 to 1.34)
ABA vs. INF | 0.94 (0.58 to 1.65) | 0.92 (0.49 to 2.29) | 0.80 (0.47 to 1.38) | 1.01 (0.75 to 1.35)
ABA vs. RIT | 0.84 (0.39 to 2.08) | 0.88 (0.34 to 1.53) | 0.89 (0.49 to 1.60) | 1.03 (0.64 to 1.67)
ABA vs. TOC | 0.80 (0.47 to 1.57) | 0.76 (0.38 to 2.44) | 0.77 (0.48 to 1.25) | 0.82 (0.60 to 1.13)
ADA vs. ANA | 1.88 (1.01 to 3.98) | 1.95 (0.82 to 4.61) | 2.08 (1.12 to 3.83) | 2.20 (1.49 to 3.26)
ADA vs. ETA^a^ | 0.29 (0.13 to 0.73) | 0.32 (0.12 to 0.84) | 0.33 (0.15 to 0.75) | 0.50 (0.32 to 0.78)
ADA vs. GOL | 0.80 (0.36 to 2.14) | 0.87 (0.27 to 2.82) | 0.90 (0.41 to 1.97) | 0.93 (0.53 to 1.59)
ADA vs. INF | 1.39 (0.86 to 2.53) | 1.42 (0.72 to 2.81) | 1.26 (0.67 to 2.35) | 1.22 (0.91 to 1.63)
ADA vs. RIT | 1.25 (0.61 to 3.04) | 1.30 (0.47 to 3.60) | 1.39 (0.71 to 2.72) | 1.25 (0.79 to 1.98)
ADA vs. TOC | 1.19 (0.74 to 2.27) | 1.20 (0.60 to 2.44) | 1.21 (0.68 to 2.16) | 1.00 (0.75 to 1.32)
ANA vs. ETA | 0.14 (0.06 to 0.41) | 0.16 (0.06 to 0.47) | 0.16 (0.07 to 0.36) | 0.23 (0.13 to 0.38)
ANA vs. GOL | 0.39 (0.16 to 1.18) | 0.45 (0.12 to 1.60) | 0.43 (0.20 to 0.95) | 0.42 (0.23 to 0.77)
ANA vs. INF | 0.68 (0.36 to 1.47) | 0.71 (0.31 to 1.63) | 0.61 (0.32 to 1.13) | 0.55 (0.37 to 0.82)
ANA vs. RIT | 0.61 (0.27 to 1.70) | 0.67 (0.22 to 1.97) | 0.67 (0.34 to 1.31) | 0.57 (0.33 to 0.96)
ANA vs. TOC | 0.58 (0.32 to 1.30) | 1.00 (0.45 to 2.21) | 0.59 (0.33 to 1.04) | 0.45 (0.31 to 0.67)
ETA vs. GOL | 2.39 (0.92 to 8.64) | 2.77 (0.72 to 10.62) | 2.70 (1.05 to 6.96) | 1.85 (0.98 to 3.51)
ETA vs. INF | 4.17 (2.00 to 11.20) | 4.34 (1.62 to 11.60) | 3.78 (1.66 to 8.58) | 2.45 (1.56 to 3.82)
ETA vs. RIT | 3.76 (1.51 to 12.70) | 4.15 (1.24 to 13.88) | 4.18 (1.78 to 9.82) | 2.50 (1.41 to 4.43)
ETA vs. TOC | 3.59 (1.73 to 9.80) | 3.63 (1.32 to 9.98) | 3.65 (1.67 to 7.98) | 2.00 (1.28 to 3.12)
GOL vs. INF | 1.47 (0.68 to 4.05) | 1.63 (0.51 to 5.20) | 1.40 (0.63 to 3.08) | 1.32 (0.77 to 2.28)
GOL vs. RIT | 1.33 (0.53 to 4.54) | 1.50 (0.24 to 4.93) | 1.55 (0.68 to 3.53) | 1.35 (0.70 to 2.60)
GOL vs. TOC | 1.27 (0.59 to 3.57) | 1.37 (0.38 to 1.97) | 1.35 (0.64 to 2.86) | 1.08 (0.63 to 1.86)
INF vs. RIT | 0.87 (0.41 to 2.07) | 0.93 (0.34 to 2.51) | 1.11 (0.56 to 2.19) | 1.02 (0.64 to 1.62)
INF vs. TOC | 0.83 (0.51 to 1.52) | 0.72 (0.38 to 1.38) | 0.97 (0.54 to 1.74) | 0.82 (0.62 to 1.08)
RIT vs. TOC | 0.84 (0.42 to 2.12) | 0.84 (0.26 to 2.77) | 0.87 (0.46 to 1.65) | 0.80 (0.51 to 1.26)

a The Bayesian MTC method and the Bucher method produced the same precision and therefore are shaded the same (i.e., they tied for second most precise for this comparison)

Abbreviations: ABA = abatacept; ADA = adalimumab; ANA = anakinra; ETA = etanercept; GOL = golimumab; INF = infliximab; RIT = rituximab; TOC = tocilizumab

Table E-4 Comparison of response for second-generation antidepressants for placebo star sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
BUP vs. DES | 0.73 (0.43 to 1.35) | 0.78 (0.30 to 2.01) | 0.77 (0.40 to 1.50) | 0.87 (0.64 to 1.18)
BUP vs. DUL | 0.84 (0.51 to 1.49) | 0.85 (0.50 to 1.45) | 0.87 (0.56 to 1.36) | 0.94 (0.70 to 1.26)
BUP vs. ESC | 0.94 (0.43 to 2.56) | 1.04 (0.21 to 5.11) | 1.04 (0.59 to 1.85) | 1.08 (0.72 to 1.63)
BUP vs. FLUO | 0.94 (0.56 to 1.72) | 0.98 (0.56 to 1.71) | 0.98 (0.62 to 1.56) | 0.99 (0.73 to 1.33)
BUP vs. FLUV | 0.39 (0.11 to 2.63) | 0.59 (0.02 to 15.83) | 0.58 (0.14 to 2.46) | 0.82 (0.26 to 2.54)
BUP vs. NEF | 0.58 (0.27 to 1.49) | 0.65 (0.19 to 2.18) | 0.82 (0.35 to 1.91) | 1.00 (0.51 to 1.98)
BUP vs. PAR | 0.67 (0.37 to 1.39) | 0.94 (0.45 to 1.99) | 0.71 (0.38 to 1.33) | 0.84 (0.57 to 1.23)
BUP vs. SER | 0.78 (0.47 to 1.41) | 0.80 (0.49 to 1.30) | 0.80 (0.52 to 1.24) | 0.96 (0.72 to 1.27)
BUP vs. VEN | 0.69 (0.38 to 1.43) | 0.74 (0.33 to 1.62) | 0.73 (0.42 to 1.28) | 0.80 (0.55 to 1.17)
DES vs. DUL | 1.11 (0.73 to 1.79) | 1.10 (0.59 to 2.03) | 1.14 (0.63 to 2.05) | 1.08 (0.86 to 1.34)
DES vs. ESC | 1.25 (0.59 to 3.13) | 1.35 (0.22 to 8.18) | 1.35 (0.67 to 2.71) | 1.24 (0.86 to 1.79)
DES vs. FLUO | 1.25 (0.81 to 2.04) | 1.27 (0.64 to 2.54) | 1.27 (0.69 to 2.34) | 1.14 (0.86 to 1.50)
DES vs. FLUV | 0.51 (0.14 to 3.45) | 0.76 (0.06 to 10.14) | 0.76 (0.17 to 3.37) | 0.94 (0.31 to 2.88)
DES vs. NEF | 0.77 (0.37 to 1.85) | 0.83 (0.21 to 3.27) | 1.07 (0.42 to 2.71) | 1.15 (0.60 to 2.23)
DES vs. PAR | 0.89 (0.52 to 1.69) | 1.23 (0.51 to 2.96) | 0.93 (0.44 to 1.94) | 0.97 (0.69 to 1.35)
DES vs. SER | 1.03 (0.66 to 1.69) | 1.05 (0.57 to 1.93) | 1.04 (0.58 to 1.87) | 1.10 (0.85 to 1.43)
DES vs. VEN | 0.92 (0.53 to 1.75) | 0.95 (0.36 to 2.54) | 0.96 (0.48 to 1.89) | 0.92 (0.65 to 1.30)
DUL vs. ESC | 1.10 (0.53 to 2.70) | 1.23 (0.54 to 2.82) | 1.19 (0.73 to 1.94) | 1.16 (0.85 to 1.58)
DUL vs. FLUO | 1.10 (0.73 to 1.72) | 1.12 (0.75 to 1.68) | 1.12 (0.79 to 1.59) | 1.06 (0.81 to 1.37)
DUL vs. FLUV | 0.45 (0.12 to 3.03) | 0.69 (0.11 to 4.35) | 0.67 (0.16 to 2.72) | 0.88 (0.29 to 2.67)
DUL vs. NEF | 0.68 (0.33 to 1.61) | 0.77 (0.33 to 1.79) | 0.94 (0.43 to 2.07) | 1.07 (0.56 to 2.06)
DUL vs. PAR | 0.78 (0.47 to 1.45) | 1.08 (0.66 to 1.77) | 0.82 (0.47 to 1.41) | 0.90 (0.67 to 1.21)
DUL vs. SER | 0.91 (0.61 to 1.43) | 0.92 (0.64 to 1.31) | 0.92 (0.67 to 1.25) | 1.02 (0.80 to 1.31)
DUL vs. VEN | 0.81 (0.48 to 1.49) | 0.92 (0.54 to 1.59) | 0.84 (0.53 to 1.34) | 0.85 (0.61 to 1.19)
ESC vs. FLUO | 0.86 (0.41 to 2.17) | 0.94 (0.42 to 2.11) | 0.94 (0.57 to 1.57) | 0.91 (0.62 to 1.34)
ESC vs. FLUV | 0.35 (0.09 to 2.86) | IS | 0.56 (0.13 to 2.40) | 0.76 (0.24 to 2.39)
ESC vs. NEF | 0.53 (0.21 to 1.79) | IS | 0.79 (0.33 to 1.88) | 0.93 (0.45 to 1.89)
ESC vs. PAR | 0.61 (0.27 to 1.69) | 0.69 (0.15 to 3.13) | 1.15 (0.71 to 1.88) | 0.78 (0.51 to 1.18)
ESC vs. SER | 0.71 (0.34 to 1.79) | 0.77 (0.39 to 1.52) | 0.77 (0.47 to 1.24) | 0.88 (0.61 to 1.29)
ESC vs. VEN | 0.63 (0.29 to 1.72) | 0.71 (0.14 to 3.46) | 0.71 (0.39 to 1.28) | 0.74 (0.48 to 1.14)
FLUO vs. FLUV | 0.40 (0.11 to 2.63) | 0.60 (0.09 to 4.02) | 0.60 (0.15 to 2.44) | 0.83 (0.27 to 2.55)
FLUO vs. NEF | 0.60 (0.29 to 1.45) | 0.66 (0.28 to 1.56) | 0.84 (0.38 to 1.86) | 1.01 (0.52 to 1.98)
FLUO vs. PAR | 0.69 (0.40 to 1.30) | 0.73 (0.39 to 1.37) | 0.73 (0.41 to 1.28) | 0.85 (0.60 to 1.20)
FLUO vs. SER | 0.81 (0.53 to 1.28) | 0.82 (0.54 to 1.23) | 0.82 (0.58 to 1.15) | 0.97 (0.73 to 1.28)
FLUO vs. VEN | 0.72 (0.42 to 1.33) | 0.75 (0.42 to 1.35) | 0.75 (0.46 to 1.22) | 0.81 (0.59 to 1.11)
FLUV vs. NEF | 0.79 (0.21 to 6.67) | IS | 1.40 (0.29 to 6.80) | 1.22 (0.34 to 4.35)
FLUV vs. PAR | 0.93 (0.26 to 6.67) | 1.61 (0.13 to 20.02) | IS | 1.02 (0.33 to 3.20)
FLUV vs. SER | 1.08 (0.31 to 7.69) | 1.37 (0.23 to 8.11) | IS | 1.17 (0.38 to 3.57)
FLUV vs. VEN | 0.96 (0.27 to 7.14) | 1.26 (0.05 to 35.00) | 1.26 (0.30 to 5.32) | 0.98 (0.31 to 3.05)
NEF vs. PAR | 1.01 (0.47 to 2.70) | 1.46 (0.47 to 4.51) | 0.87 (0.35 to 2.15) | 0.84 (0.42 to 1.68)
NEF vs. SER | 1.16 (0.57 to 2.86) | 1.23 (0.56 to 2.67) | 0.98 (0.44 to 2.14) | 0.95 (0.49 to 1.85)
NEF vs. VEN | 1.04 (0.48 to 2.78) | 0.84 (0.29 to 2.41) | 0.90 (0.38 to 2.11) | 0.80 (0.40 to 1.61)
PAR vs. SER | 1.09 (0.63 to 2.04) | 1.14 (0.71 to 1.84) | 1.12 (0.65 to 1.93) | 1.14 (0.81 to 1.61)
PAR vs. VEN | 0.97 (0.52 to 2.04) | 0.78 (0.36 to 1.70) | 1.03 (0.54 to 1.96) | 0.95 (0.63 to 1.43)
SER vs. VEN | 0.87 (0.51 to 1.61) | 0.92 (0.55 to 1.54) | 0.92 (0.58 to 1.45) | 0.84 (0.59 to 1.18)

Abbreviations: BUP = bupropion; CIT = citalopram; DES = desvenlafaxine; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; MIR = mirtazapine; NA = not applicable; NEF = nefazodone; PAR = paroxetine; SER = sertraline; TRA = trazodone; VEN = velafaxine

Table E-5 Comparison of response for second-generation antidepressants for loop sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
FLUO vs. PAR via SER | 0.83 (0.64 to 1.11) | 0.88 (0.19 to 4.02) | 0.88 (0.44 to 1.76) | 0.73 (0.51 to 1.05)
FLUO vs. PAR via placebo | Same as above | 0.73 (0.39 to 1.37) | 0.73 (0.41 to 1.28) | 0.85 (0.60 to 1.20)
FLUO vs. SER via PAR | 0.76 (0.61 to 0.96) | 0.69 (0.26 to 1.83) | 0.69 (0.34 to 1.37) | 0.86 (0.64 to 1.16)
FLUO vs. SER via placebo | Same as above | 0.82 (0.54 to 1.23) | 0.82 (0.58 to 1.15) | 0.97 (0.73 to 1.28)
PAR vs. SER via FLUO | 0.90 (0.68 to 1.25) | 0.71 (0.41 to 1.22) | 0.71 (0.46 to 1.10) | 0.73 (0.51 to 1.05)
PAR vs. SER via placebo | Same as above | 1.14 (0.71 to 1.84) | 1.12 (0.65 to 1.93) | 1.14 (0.81 to 1.61)

Abbreviations: FLUO = fluoxetine; NA = not applicable; PAR = paroxetine; SER = sertraline

Table E-6 Comparison of response for second-generation antidepressants for one closed loop sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-regression | Bucher method | Logistic regression
BUP vs. CIT | 0.74 (0.30 to 2.27) | NA | NA | 0.94 (0.49 to 1.80)
BUP vs. ESC | 0.91 (0.46 to 2.13) | NA | NA | 0.95 (0.55 to 1.64)
BUP vs. FLUO | 0.99 (0.65 to 1.61) | IS | IS | 1.07 (0.81 to 1.40)
BUP vs. FLUV | 0.78 (0.28 to 3.13) | NA | NA | 1.18 (0.53 to 2.65)
BUP vs. MIR | 1.32 (0.62 to 3.85) | IS | IS | 1.10 (0.51 to 2.35)
BUP vs. PAR | 0.83 (0.51 to 1.43) | IS | IS | 0.89 (0.64 to 1.23)
BUP vs. SER | 0.77 (0.52 to 1.18) | Direct | Direct | 0.87 (0.67 to 1.13)
BUP vs. TRA | 2.04 (1.02 to 4.76) | Direct | Direct | 1.75 (0.96 to 3.18)
CIT vs. ESC | 1.11 (0.63 to 2.17) | Direct | Direct | 1.01 (0.61 to 1.68)
CIT vs. FLUO | 1.09 (0.50 to 2.94) | IS | IS | 1.14 (0.62 to 2.09)
CIT vs. FLUV | 1.05 (0.58 to 2.08) | NA | NA | 1.26 (0.71 to 2.21)
CIT vs. MIR | 1.37 (0.44 to 7.14) | NA | NA | 1.17 (0.45 to 3.07)
CIT vs. PAR | 0.91 (0.40 to 2.56) | NA | NA | 0.95 (0.50 to 1.79)
CIT vs. SER | 0.84 (0.37 to 2.33) | NA | NA | 0.93 (0.50 to 1.73)
CIT vs. TRA | 2.08 (0.70 to 10.00) | NA | NA | 1.86 (0.80 to 4.35)
ESC vs. FLUO | 0.98 (0.53 to 1.92) | Direct | Direct | 1.12 (0.69 to 1.82)
ESC vs. FLUV | 0.85 (0.39 to 2.27) | IS | IS | 1.24 (0.60 to 2.56)
ESC vs. MIR | 1.22 (0.42 to 5.56) | NA | NA | 1.15 (0.47 to 2.83)
ESC vs. PAR | 0.81 (0.42 to 1.67) | IS | IS | 0.93 (0.55 to 1.58)
ESC vs. SER | 0.75 (0.40 to 1.54) | IS | IS | 0.91 (0.55 to 1.52)
ESC vs. TRA | 1.89 (0.70 to 7.14) | NA | NA | 1.84 (0.85 to 3.98)
FLUO vs. FLUV | 0.78 (0.31 to 2.86) | NA | NA | 1.11 (0.51 to 2.40)
FLUO vs. MIR | 1.27 (0.52 to 4.35) | NA | NA | 1.03 (0.47 to 2.23)
FLUO vs. PAR via SER | 0.83 (0.65 to 1.10) | IS | IS | 0.83 (0.65 to 1.06)
FLUO vs. PAR via placebo | NA/same | 0.73 (0.39 to 1.37) | 0.73 (0.41 to 1.28) | NA/same
FLUO vs. SER | 0.77 (0.63 to 0.96) | 0.82 (0.54 to 1.23) | 0.82 (0.58 to 1.15) | 0.81 (0.67 to 1.00)
FLUO vs. TRA | 1.96 (0.87 to 5.88) | NA | NA | 1.64 (0.88 to 3.05)
MIR vs. PAR | 0.50 (0.19 to 1.61) | NA | NA | 0.81 (0.37 to 1.80)
MIR vs. SER | 0.47 (0.18 to 1.43) | NA | NA | 0.79 (0.36 to 1.73)
MIR vs. TRA | 1.45 (0.91 to 2.50) | Direct | Direct | 1.59 (0.92 to 2.76)
PAR vs. SER via FLUO | 0.91 (0.68 to 1.27) | IS | IS | 0.98 (0.75 to 1.28)
PAR vs. SER via placebo | NA/same | 1.14 (0.71 to 1.84) | 1.12 (0.65 to 1.93) | NA/same
PAR vs. TRA | 2.33 (1.02 to 7.14) | NA | NA | 1.97 (1.03 to 3.76)
SER vs. TRA | 2.56 (1.16 to 7.14) | IS | IS | 2.01 (1.08 to 3.75)

Abbreviations: BUP = bupropion; CIT = citalopram; ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; MIR = mirtazapine; NA = not applicable; PAR = paroxetine; SER = sertraline; TRA = trazodone

Table E-7 Comparison of response for second-generation antidepressants for ladder sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
BUP vs. CIT | 0.75 (0.28 to 2.56) | NA | NA | 1.36 (0.72 to 2.58)
BUP vs. DUL | 1.20 (0.58 to 2.94) | NA | NA | 1.43 (0.90 to 2.28)
BUP vs. ESC | 0.94 (0.41 to 2.44) | NA | NA | 1.24 (0.76 to 2.03)
BUP vs. FLUO | 1.20 (0.68 to 2.44) | NA | NA | 1.25 (0.83 to 1.90)
BUP vs. FLUV | 0.79 (0.26 to 3.57) | NA | NA | 1.82 (0.82 to 4.03)
BUP vs. MIR | 1.30 (0.56 to 3.57) | IS | 0.67 (0.26 to 1.69) | 1.38 (0.65 to 2.91)
BUP vs. PAR | 1.10 (0.56 to 2.38) | NA | NA | 1.22 (0.79 to 1.90)
BUP vs. SER | 0.95 (0.68 to 1.39) | Direct | Direct | 1.08 (0.77 to 1.51)
BUP vs. TRA | 2.00 (0.99 to 5.00) | Direct | Direct | 2.14 (1.18 to 3.86)
BUP vs. VEN | 0.79 (0.47 to 1.45) | 0.82 (0.38 to 1.79) | 0.82 (0.51 to 1.34) | 0.98 (0.65 to 1.48)
CIT vs. DUL | 1.39 (0.74 to 3.13) | 1.52 (0.23 to 10.02) | 1.44 (0.78 to 2.64) | 1.05 (0.64 to 1.74)
CIT vs. ESC | 1.11 (0.63 to 2.27) | Direct | Direct | 0.91 (0.56 to 1.47)
CIT vs. FLUO | 1.32 (0.63 to 3.57) | NA | NA | 0.92 (0.53 to 1.59)
CIT vs. FLUV | 1.05 (0.58 to 2.17) | Direct | Direct | 1.33 (0.76 to 2.33)
CIT vs. MIR | 1.27 (0.41 to 7.14) | NA | NA | 1.01 (0.41 to 2.47)
CIT vs. PAR | 1.23 (0.61 to 3.03) | NA | NA | 0.90 (0.53 to 1.53)
CIT vs. SER | 0.95 (0.41 to 3.23) | NA | NA | 0.79 (0.44 to 1.41)
CIT vs. TRA | 1.96 (0.68 to 10.00) | NA | NA | 1.57 (0.72 to 3.43)
CIT vs. VEN | 0.83 (0.37 to 2.38) | NA | NA | 0.72 (0.41 to 1.25)
DUL vs. ESC | 0.79 (0.57 to 1.06) | Direct | Direct | 0.86 (0.69 to 1.08)
DUL vs. FLUO | 0.94 (0.61 to 1.56) | 0.96 (0.58 to 1.60) | 0.97 (0.64 to 1.45) | 0.87 (0.64 to 1.20)
DUL vs. FLUV | 0.66 (0.28 to 1.96) | NA | NA | 1.27 (0.63 to 2.56)
DUL vs. MIR | 0.92 (0.33 to 3.85) | NA | NA | 0.96 (0.44 to 2.10)
DUL vs. PAR | 0.88 (0.65 to 1.25) | Direct | Direct | 0.85 (0.67 to 1.08)
DUL vs. SER | 0.69 (0.37 to 1.52) | NA | NA | 0.75 (0.52 to 1.09)
DUL vs. TRA | 1.43 (0.57 to 5.26) | NA | NA | 1.49 (0.78 to 2.86)
DUL vs. VEN | 0.60 (0.36 to 1.11) | NA | NA | 0.68 (0.49 to 0.96)
ESC vs. FLUO | 1.18 (0.71 to 2.22) | NA | NA | 1.01 (0.71 to 1.45)
ESC vs. FLUV | 0.85 (0.37 to 2.38) | IS | 0.94 (0.42 to 2.11) | 1.47 (0.73 to 2.93)
ESC vs. MIR | 1.15 (0.41 to 5.00) | NA | NA | 1.11 (0.50 to 2.48)
ESC vs. PAR | 1.10 (0.72 to 1.85) | 1.16 (0.57 to 2.36) | 1.09 (0.77 to 1.56) | 0.99 (0.72 to 1.35)
ESC vs. SER | 0.86 (0.44 to 2.13) | NA | NA | 0.87 (0.58 to 1.31)
ESC vs. TRA | 1.79 (0.69 to 7.14) | NA | NA | 1.73 (0.88 to 3.38)
ESC vs. VEN | 0.75 (0.42 to 1.56) | NA | NA | 0.79 (0.54 to 1.15)
FLUO vs. FLUV | 0.66 (0.25 to 2.22) | NA | NA | 1.45 (0.70 to 2.99)
FLUO vs. MIR | 0.97 (0.38 to 3.57) | NA | NA | 1.10 (0.51 to 2.35)
FLUO vs. PAR | 0.91 (0.66 to 1.30) | Direct | Direct | 0.98 (0.75 to 1.27)
FLUO vs. SER | 0.73 (0.45 to 1.32) | 0.90 (0.47 to 1.71) | 0.95 (0.62 to 1.45) | 0.86 (0.64 to 1.16)
FLUO vs. TRA | 1.49 (0.65 to 5.00) | NA | NA | 1.71 (0.91 to 3.18)
FLUO vs. VEN | 0.64 (0.47 to 0.87) | Direct | Direct | 0.78 (0.65 to 0.94)
FLUV vs. MIR | 1.08 (0.33 to 7.69) | NA | NA | 0.76 (0.28 to 2.09)
FLUV vs. PAR | 1.04 (0.43 to 3.45) | NA | NA | 0.67 (0.33 to 1.38)
FLUV vs. SER | 0.81 (0.29 to 3.57) | NA | NA | 0.59 (0.28 to 1.26)
FLUV vs. TRA | 1.67 (0.53 to 11.11) | NA | NA | 1.18 (0.47 to 2.94)
FLUV vs. VEN | 0.71 (0.27 to 2.70) | NA | NA | 0.54 (0.26 to 1.12)
MIR vs. PAR | 0.66 (0.24 to 2.56) | NA | NA | 0.89 (0.41 to 1.92)
MIR vs. SER | 0.57 (0.25 to 1.89) | NA | NA | 0.78 (0.37 to 1.66)
MIR vs. TRA | 1.45 (0.92 to 2.50) | Direct | Direct | 1.55 (0.90 to 2.68)
MIR vs. VEN | 0.48 (0.20 to 1.69) | NA | NA | 0.71 (0.33 to 1.52)
PAR vs. SER | 0.78 (0.45 to 1.59) | NA | NA | 0.88 (0.63 to 1.24)
PAR vs. TRA | 1.61 (0.67 to 5.88) | NA | NA | 1.75 (0.92 to 3.31)
PAR vs. VEN | 0.68 (0.44 to 1.11) | 0.83 (0.50 to 1.38) | 0.87 (0.60 to 1.25) | 0.80 (0.60 to 1.08)
SER vs. TRA | 2.04 (0.93 to 5.56) | IS | 1.03 (0.46 to2.30) | 1.99 (1.08 to 3.67)
SER vs. VEN | 0.83 (0.55 to 1.30) | Direct | Direct | 0.91 (0.68 to 1.21)
TRA vs. VEN | 0.33 (0.14 to 0.99) | NA | NA | 0.46 (0.25 to 0.86)

Abbreviations: BUP = bupropion; CIT = citalopram; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; MIR = mirtazapine; NA = not applicable; PAR = paroxetine; SER = sertraline; TRA = trazodone; VEN = venlafaxine

Table E-8 Comparison of mean change in HAM-D for second-generation antidepressants for placebo star sub-network, by method of analysis: Weighted mean difference (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method
DES vs. DUL | -0.65 (-2.80 to 1.38) | -0.65 (-2.92 to 1.61) | -0.68 (-2.25 to 0.90)
DES vs. ESC | -1.20 (-4.10 to 1.75) | -1.23 (-5.06 to 2.61) | -1.23 (-2.97 to 0.51)
DES vs. FLUO | 0.12 (-2.30 to 2.50) | 0.72 (-4.27 to 5.71) | -0.27 (-5.19 to 4.64)
DES vs. PAR | -0.88 (-3.20 to 1.24) | -0.67 (-3.33 to 2.00) | -0.72 (-2.65 to 1.21)
DES vs. SER | -0.43 (-2.60 to 1.70) | -0.41 (-2.68 to 1.86) | -0.47 (-2.15 to 1.21)
DES vs. VEN | 1.94 (-1.30 to 5.21) | 1.92 (-3.05 to 6.89) | 1.92 (-0.34 to 4.18)
DUL vs. ESC | -0.53 (-3.30 to 2.20) | -0.55 (-4.68 to 3.58) | -0.55 (-2.34 to 1.24)
DUL vs. FLUO | 0.77 (-1.40 to 2.92) | 1.15 (-3.45 to 5.76) | 0.41 (-4.53 to 5.34)
DUL vs. PAR | -0.24 (-2.20 to 1.63) | -0.04 (-2.59 to 2.51) | -0.04 (-2.02 to 1.94)
DUL vs. SER | 0.21 (-1.70 to 2.08) | 0.20 (-2.00 to 2.39) | 0.21 (-1.53 to 1.95)
DUL vs. VEN | 2.59 (-0.50 to 5.69) | 2.60 (-2.15 to 7.35) | 2.60 (0.29 to 4.91)
ESC vs. FLUO | 1.30 (-1.70 to 4.28) | 0.91 (-49.15 to 50.98) | 0.96 (-4.03 to 5.95)
ESC vs. PAR | 0.30 (-2.60 to 3.04) | 0.49 (-5.90 to 6.88) | 0.51 (-1.60 to 2.62)
ESC vs. SER | 0.75 (-2.10 to 3.54) | 0.77 (-3.44 to 4.97) | 0.76 (-1.13 to 2.65)
ESC vs. VEN | 3.12 (-0.61 to 6.85) | IS | 3.15 (0.73 to 5.57)
FLUO vs. PAR | -1.00 (-3.40 to 1.23) | -1.08 (-7.51 to 5.36) | -0.45 (-5.51 to 4.61)
FLUO vs. SER | -0.55 (-2.80 to 1.72) | -0.92 (-5.82 to 3.97) | -0.20 (-5.17 to 4.77)
FLUO vs. VEN | 1.82 (-1.50 to 5.20) | 2.24 (-48.69 to 53.16) | 2.19 (-3.00 to 7.39)
PAR vs. SER | 0.45 (-1.50 to 2.54) | 0.24 (-2.46 to 2.93) | 0.25 (-1.82 to 2.32)
PAR vs. VEN | 2.83 (-0.29 to 6.11) | 2.66 (-4.47 to 9.79) | 2.64 (0.08 to 5.20)
SER vs. VEN | 2.37 (-0.75 to 5.56) | 2.38 (-2.49 to 7.26) | 2.39 (0.01 to 4.77)

Abbreviations: DES = desvenlafaxine; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; IS = insufficient studies; PAR = paroxetine; SER = sertraline; VEN = venlafaxine

Table E-9 Comparison of mean change in HAM-D for second-generation antidepressants for loop sub-network, by method of analysis: Weighted mean difference (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Via
ESC vs. FLUO | -1.20 (-4.00 to 1.41) | 0.91 (-49.15 to 50.98) | 0.96 (-4.03 to 5.95) | Placebo
ESC vs. FLUO | -1.20 (-4.00 to 1.41) | IS | -4.74 (-8.11 to -1.36) | VEN
ESC vs. VEN | 0.65 (-2.90 to 3.94) | IS | 0.60 (-2.27 to 3.47) | FLUO
FLUO vs. VEN | 1.87 (-0.90 to 4.77) | IS | -0.90 (-4.00 to 2.20) | ESC

Abbreviations: ESC = escitalopram; FLUO = fluoxetine; IS = insufficient studies; VEN = venlafaxine

Table E-10 Comparison of mean change in HAM-D for second-generation antidepressants for one closed loop sub-network, by method of analysis: Weighted mean difference (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Via
ESC vs. FLUO | -1.20 (-4.60 to 1.80) | 0.91 (-49.15 to 50.98) | 0.96 (-4.03 to 5.95) | placebo
ESC vs. FLUO | -1.20 (-4.00 to 1.41) | IS | -4.74 (-8.11 to -1.36) | VEN
ESC vs. SER | -1.10 (-4.70 to 2.18) | 0.77 (-3.44 to 4.97) | 0.76 (-1.13 to 2.65) | placebo
ESC vs. VEN | 0.67 (-2.30 to 3.45) | IS | 0.60 (-2.27 to 3.47) | FLUO
FLUO vs. PAR | 0.04 (-2.90 to 3.24) | IS | -1.49 (-4.38 to 1.40) | TRA
FLUO vs. SER | 0.04 (-3.00 to 3.06) | -0.92 (-5.82 to 3.97) | -0.20 (-5.17 to 4.77) | placebo
FLUO vs. VEN | 1.85 (-0.50 to 4.31) | IS | -0.90 (-4.00 to 2.20) | ESC
FLUO vs. VEN | 1.85 (-0.50 to 4.31) | 2.24 (-48.69 to 53.16) | 2.19 (-3.00 to 7.39) | placebo
TRA vs. VEN | 0.93 (-2.90 to 4.61) | IS | 3.59 (0.45 to 6.73) | FLUO

Abbreviations: ESC = escitalopram; FLUO = fluoxetine; FLUV = fluvoxamine; IS = insufficient studies; NA = not applicable; PAR = paroxetine; SER = sertraline; TRA = trazodone; VEN = venlafaxine

Table E-11 Comparison of mean change in HAM-D for second-generation antidepressants for ladder sub-network, by method of analysis: Weighted mean difference (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Via
BUP vs. VEN | 1.04 (-3.50 to 5.14) | IS | -0.74 (-4.21 to 2.73) | SER
CIT vs. DUL | 0.54 (-3.90 to 4.71) | IS | 0.85 (-2.49 to 4.19) | ESC
ESC vs. PAR | -0.67 (-4.10 to 2.62) | 0.26 (-5.51 to 6.03) | -0.35 (-3.17 to 2.47) | DUL
FLUO vs. SER | 2.50 (-1.10 to 6.53) | 1.66 (-31.65 to 34.98) | 2.68 (-1.01 to 6.36) | VEN
PAR vs. VEN | 2.99 (-0.74 to 6.23) | -4.13 (-12.41 to 4.15) | 1.89 (-0.86 to 4.64) | FLUO

Abbreviations: BUP = bupropion; CIT = citalopram; DUL = duloxetine; ESC = escitalopram; FLUO = fluoxetine; IS = insufficient studies; NA = not applicable; PAR = paroxetine; SER = sertraline; VEN = venlafaxine

Table E-12 Comparison of ACR50 response for biologic DMARDs for placebo star sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. ADA | 0.59 (0.33 to 1.14) | 0.67 (0.34 to 1.33) | 0.64 (0.38 to 1.08) | 0.83 (0.60 to 1.14)
ABA vs. ANA | 1.15 (0.57 to 2.63) | 1.32 (0.63 to 2.79) | 1.32 (0.78 to 2.24) | 1.82 (1.20 to 2.76)
ABA vs. ETA | 0.17 (0.08 to 0.49) | 0.21 (0.08 to 0.57) | 0.21 (0.10 to 0.45) | 0.41 (0.26 to 0.66)
ABA vs. GOL | 0.49 (0.21 to 1.39) | 0.59 (0.18 to 1.89) | 0.57 (0.28 to 1.17) | 0.76 (0.43 to 1.34)
ABA vs. INF | 0.85 (0.48 to 1.72) | 0.92 (0.49 to 2.29) | 0.80 (0.47 to 1.38) | 1.01 (0.75 to 1.35)
ABA vs. RIT | 0.78 (0.36 to 2.00) | 0.88 (0.34 to 1.53) | 0.89 (0.49 to 1.60) | 1.03 (0.64 to 1.67)
ABA vs. TOC | 0.74 (0.42 to 1.49) | 0.76 (0.38 to 2.44) | 0.77 (0.48 to 1.25) | 0.82 (0.60 to 1.13)
ADA vs. ANA | 1.89 (0.99 to 4.00) | 1.95 (0.82 to 4.61) | 2.08 (1.12 to 3.83) | 2.20 (1.49 to 3.26)
ADA vs. ETA | 0.28 (0.13 to 0.77) | 0.32 (0.12 to 0.84) | 0.33 (0.15 to 0.75) | 0.50 (0.32 to 0.78)
ADA vs. GOL | 0.81 (0.36 to 2.13) | 0.87 (0.27 to 2.82) | 0.90 (0.41 to 1.97) | 0.93 (0.53 to 1.59)
ADA vs. INF | 1.39 (0.83 to 2.56) | 1.42 (0.72 to 2.81) | 1.26 (0.67 to 2.35) | 1.22 (0.91 to 1.63)
ADA vs. RIT | 1.27 (0.62 to 3.13) | 1.30 (0.47 to 3.60) | 1.39 (0.71 to 2.72) | 1.25 (0.79 to 1.98)
ADA vs. TOC | 1.20 (0.74 to 2.33) | 1.20 (0.60 to 2.44) | 1.21 (0.68 to 2.16) | 1.00 (0.75 to 1.32)
ANA vs. ETA | 0.14 (0.06 to 0.41) | 0.16 (0.06 to 0.47) | 0.16 (0.07 to 0.36) | 0.23 (0.13 to 0.38)
ANA vs. GOL | 0.39 (0.16 to 1.18) | 0.45 (0.12 to 1.60) | 0.43 (0.20 to 0.95) | 0.42 (0.23 to 0.77)
ANA vs. INF | 0.68 (0.36 to 1.49) | 0.71 (0.31 to 1.63) | 0.61 (0.32 to 1.13) | 0.55 (0.37 to 0.82)
ANA vs. RIT | 0.62 (0.27 to 1.72) | 0.67 (0.22 to 1.97) | 0.67 (0.34 to 1.31) | 0.57 (0.33 to 0.96)
ANA vs. TOC | 0.58 (0.32 to 1.32) | 1.00 (0.45 to 2.21) | 0.59 (0.33 to 1.04) | 0.45 (0.31 to 0.67)
ETA vs. GOL | 2.38 (0.90 to 8.33) | 2.77 (0.72 to 10.62) | 2.70 (1.05 to 6.96) | 1.85 (0.98 to 3.51)
ETA vs. INF | 4.17 (1.96 to 11.11) | 4.34 (1.62 to 11.60) | 3.78 (1.66 to 8.58) | 2.45 (1.56 to 3.82)
ETA vs. RIT | 3.85 (1.52 to 12.50) | 4.15 (1.24 to 13.88) | 4.18 (1.78 to 9.82) | 2.50 (1.14 to 4.43)
ETA vs. TOC | 3.57 (1.69 to 10.00) | 3.63 (1.32 to 9.98) | 3.65 (1.67 to 7.98) | 2.00 (1.28 to 3.12)
GOL vs. INF | 1.45 (0.68 to 4.17) | 1.63 (0.51 to 5.20) | 1.40 (0.63 to 3.08) | 1.32 (0.77 to 2.28)
GOL vs. RIT | 1.33 (0.53 to 4.76) | 1.50 (0.24 to 4.93) | 1.55 (0.68 to 3.53) | 1.35 (0.70 to 2.60)
GOL vs. TOC | 1.27 (0.59 to 3.70) | 1.37 (0.38 to 1.97) | 1.35 (0.64 to 2.86) | 1.08 (0.63 to 1.86)
INF vs. RIT | 0.88 (0.41 to 2.13) | 0.93 (0.34 to 2.51) | 1.11 (0.56 to 2.19) | 1.02 (0.64 to 1.62)
INF vs. TOC | 0.83 (0.50 to 1.56) | 0.72 (0.38 to 1.38) | 0.97 (0.54 to 1.74) | 0.82 (0.62 to 1.08)
RIT vs. TOC | 0.83 (0.41 to 2.13) | 0.84 (0.26 to 2.77) | 0.87 (0.46 to 1.65) | 0.80 (0.51 to 1.26)

Abbreviations: ABA = abatacept; ADA = adalimumab; ANA = anakinra; ETA = etanercept; GOL = golimumab; INF = infliximab; RIT = rituximab; TOC = tocilizumab

Table E-13 Comparison of ACR50 response for biologic DMARDs for loop sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. INF | 0.92 (0.50 to 1.79) | 0.90 (0.33 to 2.44) | 0.77 (0.48 to 1.25) | 0.82(0.60 to 1.13)

Abbreviations: ABA = abatacept; INF = infliximab

Table E-14 Comparison of ACR50 response for biologic DMARDs for one closed loop sub-network using Adalimumab, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. ADA | 0.62 (0.31 to 1.33) | 0.67 (0.34 to 1.33) | 0.64 (0.38 to 1.08) | 0.83 (0.60 to 1.14)
ABA vs. INF | 0.93 (0.51 to 1.89) | 0.92 (0.49 to 2.29) | 0.80 (0.47 to 1.38) | 1.01 (0.75 to 1.35)
ADA vs. INF | 1.39 (0.78 to 2.94) | 1.42 (0.72 to 2.81) | 1.26 (0.67 to 2.35) | 1.22 (0.91 to 1.63)

Abbreviations: ABA = abatacept; ADA = adalimumab; INF = infliximab

Table E-15 Comparison of ACR50 response for biologic DMARDs for one closed loop sub-network using Etanercept, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. ETA | 0.19 (0.08 to 0.52) | 0.21 (0.08 to 0.57) | 0.21 (0.10 to 0.45) | 0.41 (0.26 to 0.66)
ABA vs. INF | 0.94 (0.56 to 1.67) | 0.88 (0.34 to 2.29) | 0.80 (0.47 to 1.38) | 1.01 (0.75 to 1.35)
ETA vs. INF | 4.17 (1.96 to 11.11) | 4.34 (1.62 to 11.60) | 3.78 (1.66 to 8.58) | 2.45 (1.56 to 3.82)

Abbreviations: ABA = abatacept; ETA = etanercept; INF = infliximab

Table E-16 Comparison of ACR50 response for biologic DMARDs for ladder sub-network, by method of analysis: Odds ratios (95% credible interval or 95% confidence interval)

Comparison | Bayesian MTC | Meta-Regression | Bucher Method | Logistic Regression
ABA vs. ETA | 0.19 (0.05 to 1.05) | NA | NA | 0.79 (0.50 to 1.26)
ABA vs. INF | 0.98 (0.38 to 3.45) | Direct | Direct | 0.98 (0.65 to 1.47)
ETA vs. INF | 4.00 (1.72 to 12.50) | 4.34 (1.62 to 11.60) | 3.78 (1.66 to 8.58) | 1.24 (0.91 to 1.67)

Abbreviations: ABA = abatacept; ETA = etanercept; INF = infliximab