# Evidence Networks

Figure C-1 Response for second-generation antidepressants: Full network

The figure shows the second-generation antidepressants and placebo used in the full network analysis of response and the number of trials that contributed to each comparison. The drugs are as follows: fluoxetine, sertraline, fluvoxamine, duloxetine, bupropion, trazodone, venlafaxine, desvenlafaxine, citalopram, nefazodone, mirtazapine, paroxetine, escitalopram. There is also a placebo. Straight lines connect the drugs / placebo to each other. Three trials compared fluoxetine with sertraline. One trial compared fluoxetine with duloxetine. Six trials compared fluoxetine with placebo. One trial compared fluoxetine with nefazodone. Eight trials compared fluoxetine with venlafaxine. Five trials compared fluoxetine with paroxetine. One trial compared fluoxetine with mirtazapine. Two trials compared fluoxetine with bupropion. Three trials compared sertraline with bupropion. One trial compared sertraline with trazodone. Seven trials compared sertraline with placebo. One trial compared sertraline with paroxetine. Three trials compared sertraline with venlafaxine. One trial compared sertraline with nefazodone. One trial compared fluvoxamine with placebo. One trial compared fluvoxamine with citalopram. One trial compared bupropion with trazodone. Three trials compared bupropion with placebo. One trial compared trazodone with mirtazapine. One trial compared trazodone with paroxetine. One trial compared mirtazapine with paroxetine. Four trials compared paroxetine with placebo. Three trials compared paroxetine with duloxetine. One trial compared paroxetine with nefazodone. One trial compared paroxetine with escitalopram. Three trials compared venlafaxine with placebo. One trial compared venlafaxine with escitalopram. One trial compared escitalopram with fluoxetine. One trial compared escitalopram with placebo. Three trials compared escitalopram with duloxetine. One trial compared escitalopram with citalopram. One trial compared duloxetine with desvenlafaxine. Five trials compared desvenlafaxine with placebo. Eight trials compared duloxetine with placebo. Two trials compared nefazodone with placebo.

Figure C-2 Response for second-generation antidepressants: Star sub-network

The figure shows the second-generation antidepressants and placebo used in the star sub-network analysis of response and the number of trials that contributed to each comparison. The following drugs are arranged in a circle with placebo at the center: bupropion, fluoxetine, sertraline, fluvoxamine, duloxetine, desvenlafaxine, nefazodone, escitalopram, venlafaxine, and paroxetine. Straight lines connect placebo to each drug. Three trials compared bupropion with placebo. Six trials compared fluoxetine with placebo. Seven trials compared sertraline with placebo. One trial compared fluvoxamine with placebo. Eight trials compared duloxetine with placebo. Five trials compared desvenlafaxine with placebo. Two trials compared nefazodone with placebo. One trial compared escitalopram with placebo. Three trials compared venlafaxine with placebo. Four trials compared paroxetine with placebo.

Figure C-3 Response for second-generation antidepressants: Loop sub-network

The figure shows the second-generation antidepressants and placebo used in the loop sub-network analysis of response and the number of trials that contributed to each comparison. Three drugs appear in the figure: sertraline, fluoxetine, and paroxetine. There is also a placebo. They are arranged in a square, with one drug / placebo at each corner. Straight lines connect each drug / placebo. Seven trials compared sertraline with placebo. Three trials compared sertraline with fluoxetine. Five trials compared fluoxetine with paroxetine. Four trials compared paroxetine with placebo. Six trials compared fluoxetine with placebo. One trial compared sertraline with paroxetine.

Figure C-4 Response for second-generation antidepressants: One closed loop sub-network

The figure shows the second-generation antidepressants and placebo used in the one closed loop sub-network analysis of response and the number of trials that contributed to each comparison. Nine drugs appear in the figure: sertraline, fluoxetine, paroxetine, mirtazapine, trazodone, bupropion, escitalopram, citalopram, and fluvoxamine. There is also a placebo. Three of the drugs (paroxetine, sertraline, and fluoxetine) and the placebo are arranged in a square, with one drug / placebo at each corner. Straight lines connect each drug / placebo. Seven trials compared sertraline with placebo. Three trials compared sertraline with fluoxetine. Five trials compared fluoxetine with paroxetine. Four trials compared paroxetine with placebo. Six trials compared fluoxetine with placebo. One trial compared sertraline with paroxetine. The other six drugs are connected to the square via each other, in two sets of three drugs. In the first set, 3 trials compared sertraline with bupropion, 1 trial compared bupropion with trazodone, and 1 trial compared trazodone with mirtazapine. On the other side, 1 trial compared fluoxetine with escitalopram, 1 trial compared escitalopram with citalopram, and 1 trial compared citalopram with fluvoxamine.

Figure C-5 Response for second-generation antidepressants: Ladder sub-network

The figure shows the second-generation antidepressants and placebo used in the ladder sub-network analysis of response and the number of trials that contributed to each comparison. Each drug / placebo is connected to another via a single comparison. One trial compared mirtazapine with trazodone. One trial compared trazodone with bupropion. Three trials compared bupropion with sertraline. Three trials compared sertraline with venlafaxine. Eight trials compared venlafaxine with fluoxetine. Five trials compared fluoxetine with paroxetine. Three trials compared paroxetine with duloxetine. Three trials compared duloxetine with escitalopram. One trial compared escitalopram with citalopram. One trial compared citalopram with fluvoxamine.

Figure C-6 Response for second-generation antidepressants: Full network, including studies in older adults (meta-regression for Key Question 2)

The figure shows the second-generation antidepressants and placebo used in the full network analysis of response, including studies in older adults, and the number of trials that contributed to each comparison. The drugs are as follows: fluoxetine, sertraline, fluvoxamine, duloxetine, bupropion, trazodone, venlafaxine, desvenlafaxine, citalopram, nefazodone, mirtazapine, paroxetine, and escitalopram. There is also a placebo. Straight lines connect the drugs / placebo to each other. Four trials compared fluoxetine with sertraline. One trial compared fluoxetine with duloxetine. Seven trials compared fluoxetine with placebo. One trial compared fluoxetine with nefazodone. Eight trials compared fluoxetine with venlafaxine. Five trials compared fluoxetine with paroxetine. One trial compared fluoxetine with mirtazapine. Two trials compared fluoxetine with bupropion. Three trials compared sertraline with bupropion. One trial compared sertraline with trazodone. Eight trials compared sertraline with placebo. One trial compared sertraline with paroxetine. Three trials compared sertraline with venlafaxine. One trial compared sertraline with nefazodone. One trial compared fluvoxamine with placebo. One trial compared fluvoxamine with citalopram. One trial compared bupropion with trazodone. Three trials compared bupropion with placebo. Two trials compared trazodone with mirtazapine. One trial compared trazodone with paroxetine. One trial compared mirtazapine with paroxetine. Five trials compared paroxetine with placebo. Three trials compared paroxetine with duloxetine. One trial compared paroxetine with nefazodone. One trial compared paroxetine with escitalopram. Three trials compared venlafaxine with placebo. One trial compared venlafaxine with escitalopram. One trial compared escitalopram with fluoxetine. One trial compared escitalopram with placebo. Three trials compared escitalopram with duloxetine. One trial compared escitalopram with citalopram. One trial compared duloxetine with desvenlafaxine. Five trials compared desvenlafaxine with placebo. Eight trials compared duloxetine with placebo. Two trials compared nefazodone with placebo. One trial compared fluvoxamine with sertraline. One trial compared trazodone with placebo. One trial compared mirtazapine with placebo. One trial compared bupropion with paroxetine. One trial compared citalopram with placebo.

Figure C-7 Mean change in HAM-D for second-generation antidepressants: Full network

The figure shows the second-generation antidepressants and placebo used in the full network analysis of mean change in HAM-D and the number of studies that contributed to each comparison. The drugs are as follows: fluoxetine, sertraline, fluvoxamine, duloxetine, bupropion, trazodone, venlafaxine, desvenlafaxine, citalopram, nefazodone, mirtazapine, paroxetine, and escitalopram. There is also a placebo. Straight lines connect the drugs / placebo to each other. Two studies compared sertraline with fluvoxamine. Four studies compared sertraline with placebo. One study compared sertraline with escitalopram. Two studies compared sertraline with venlafaxine. One study compared sertraline with trazodone. One study compared sertraline with bupropion. Two studies compared fluoxetine with trazodone. Three studies compared fluoxetine with paroxetine. Two studies compared fluoxetine with venlafaxine. One study compared fluoxetine with nefazodone. One study compared fluoxetine with escitalopram. Three studies compared fluoxetine with placebo. One study compared trazodone with paroxetine. One study compared mirtazapine with paroxetine. Two studies compared paroxetine with venlafaxine. One study compared venlafaxine with placebo. One study compared venlafaxine with escitalopram. Two studies compared paroxetine with duloxetine. Two studies compared paroxetine with fluvoxamine. Four studies compared paroxetine with placebo. Four studies compared duloxetine with placebo. Three studies compared desvenlafaxine with placebo. Two studies compared duloxetine with escitalopram. One study compared escitalopram with placebo. One study compared escitalopram with citalopram.

Figure C-8 Mean change in HAM-D for second-generation antidepressants: Star sub-network

The figure shows the second-generation antidepressants and placebo used in the star sub-network analysis of mean change in HAM-D and the number of studies that contributed to each comparison. The following drugs are arranged in a circle with placebo at the center: fluoxetine, sertraline, duloxetine, desvenlafaxine, escitalopram, venlafaxine, and paroxetine. Straight lines connect placebo to each drug. Three studies compared fluoxetine with placebo. Four studies compared sertraline with placebo. Four studies compared duloxetine with placebo. Three studies compared desvenlafaxine with placebo. One study compared escitalopram with placebo. One study compared venlafaxine with placebo. Four studies compared paroxetine with placebo.

Figure C-9 Mean change in HAM-D for second-generation antidepressants: Loop sub-network

The figure shows the second-generation antidepressants and placebo used in the loop sub-network analysis of mean change in HAM-D and the number of studies that contributed to each comparison. Three drugs appear in the figure: fluoxetine, venlafaxine, and escitalopram. There is also a placebo. They are arranged in a diamond shape, with one drug / placebo at each corner. Straight lines connect each drug / placebo. Three studies compared fluoxetine with placebo. One study compared escitalopram with placebo. One study compared escitalopram with venlafaxine. Two studies compared venlafaxine with fluoxetine. One study compared fluoxetine with escitalopram. One study compared venlafaxine with placebo.

Figure C-10 Mean change in HAM-D for second-generation antidepressants: One closed loop sub-network

The figure shows the second-generation antidepressants and placebo used in the one closed loop sub-network analysis of mean change in HAM-D and the number of studies that contributed to each comparison. Eight drugs appear in the figure: paroxetine, trazodone, fluoxetine, venlafaxine, escitalopram, sertraline, and fluvoxamine. There is also a placebo. Three of the drugs (fluoxetine, velafaxine, and escitalopram) and the placebo are arranged in a diamond shape, with one drug / placebo at each corner. Straight lines connect each drug / placebo. Three studies compared fluoxetine with placebo. One study compared escitalopram with placebo. One study compared escitalopram with venlafaxine. Two studies compared venlafaxine with fluoxetine. One study compared fluoxetine with escitalopram. One study compared venlafaxine with placebo. The other four drugs are connected to the diamond via each other, in two sets of two drugs. In the first set, 1 study compared paroxetine with trazodone, and 2 studies compared trazodone with fluoxetine. On the other side, 4 studies compared sertraline with placebo, and 2 studies compared sertraline with fluvoxamine.

Figure C-11 Mean change in HAM-D for second-generation Antidepressants: Ladder sub-network

The figure shows the second-generation antidepressants and placebo used in the ladder sub-network analysis of mean change in HAM-D and the number of studies that contributed to each comparison. Each drug / placebo is connected to another via a single comparison. One study compared bupropion with sertraline. Two studies compared sertraline with venlafaxine. Two studies compared venlafaxine with fluoxetine. Three studies compared fluoxetine with paroxetine. Two studies compared paroxetine with duloxetine. Two studies compared duloxetine with escitalopram. One study compared escitalopram with citalopram.

Figure C-12 ACR50 response for biologic DMARDs: Full network

The figure shows the biologic DMARDs and placebo used in the full network analysis of ACR50 response and the number of trials that contributed to each comparison. The drugs are as follows: abatacept, infliximab, golimumab, adalimumab, tocilizumab, rituximab, etanercept, and anakinra. There is also a placebo. Straight lines connect the drugs / placebo to each other. One trial compared abatacept with infliximab. Three trials compared abatacept with placebo. Six trials compared infliximab with placebo. Two trials compared golimumab with placebo. Seven trials compared adalimumab with placebo. Four trials compared tocilizumab with placebo. Two trials compared rituximab with placebo. Four trials compared etanercept with placebo. Three trials compared anakinra with placebo.

Figure C-13 ACR50 response for biologic DMARDs: Star sub-network

The figure shows the biologic DMARDs and placebo used in the star sub-network analysis of ACR50 response and the number of trials that contributed to each comparison. The following drugs are arranged in a circle with placebo at the center: abatacept, infliximab, golimumab, adalimumab, tocilizumab, rituximab, etanercept, and anakinra. Straight lines connect placebo to each drug. Three trials compared abatacept with placebo. Six trials compared infliximab with placebo. Two trials compared golimumab with placebo. Seven trials compared adalimumab with placebo. Four trials compared tocilizumab with placebo. Two trials compared rituximab with placebo. Four trials compared etanercept with placebo. Three trials compared anakinra with placebo.

Figure C-14 ACR50 response for biologic DMARDs: Loop sub-network

The figure shows the biologic DMARDs and placebo used in the loop sub-network analysis of ACR50 response and the number of trials that contributed to each comparison. Two drugs appear in the figure: abatacept and infliximab. There is also a placebo. They are arranged in a triangle, with one drug / placebo at each corner. Straight lines connect each drug / placebo. One trial compared abatacept with infliximab. Six trials compared infliximab with placebo. Three trials compared abatacept with placebo.

Figure C-15 ACR50 response for biologic DMARDs: One closed loop sub-network using Adalimumab

The figure shows the biologic DMARDs and placebo used in the one closed loop sub-network analysis of ACR50 response using adalimumab and the number of studies that contributed to each comparison. Three drugs appear in the figure: abatacept, infliximab, and adalimumab. There is also a placebo. Abatacept, infliximab, and placebo are arranged in a triangle, with one drug / placebo at each corner. Adalimumab is connected to the triangle via placebo. Straight lines connect each drug / placebo. One trial compared abatacept with infliximab. Six trials compared infliximab with placebo. Three trials compared abatacept with placebo. Seven trials compared adalimumab with placebo.

Figure C-16 ACR50 response for biologic DMARDs: One closed loop sub-network using Etanercept

The figure shows the biologic DMARDs and placebo used in the one closed loop sub-network analysis of ACR50 response using etanercept and the number of studies that contributed to each comparison. Three drugs appear in the figure: abatacept, infliximab, and etanercept. There is also a placebo. Abatacept, infliximab, and placebo are arranged in a triangle, with one drug / placebo at each corner. Etanercept is connected to the triangle via placebo. Straight lines connect each drug / placebo. One trial compared abatacept with infliximab. Six trials compared infliximab with placebo. Three trials compared abatacept with placebo. Four trials compared etanercept with placebo.

Figure C-17 ACR50 response for biologic DMARDs: Ladder sub-network using Adalimumab

The figure shows the biologic DMARDs and placebo used in the ladder sub-network analysis of ACR50 response using adalimumab and the number of studies that contributed to each comparison. Three drugs appear in the figure: abatacept, infliximab, and adalimumab. There is also a placebo. Straight lines connect each drug / placebo. One trial compared abatacept with infliximab. Six trials compared infliximab with placebo. Seven trials compared adalimumab with placebo.

Figure C-18 ACR50 response for biologic DMARDs: Ladder sub-network using Etanercept

The figure shows the biologic DMARDs and placebo used in the ladder sub-network analysis of ACR50 response using etanercept and the number of studies that contributed to each comparison. Three drugs appear in the figure: abatacept, infliximab, and etanercept. There is also a placebo. Straight lines connect each drug / placebo. One trial compared abatacept with infliximab. Six trials compared infliximab with placebo. Four trials compared adalimumab with placebo.

Figure C-19 ACR50 response for biologic DMARDs: Full network excluding studies that did not report disease duration (meta-regression for Key Question 2)

The figure shows the biologic DMARDs and placebo used in the full network analysis of ACR50 response and the number of trials that contributed to each comparison. The drugs are as follows: abatacept, infliximab, golimumab, adalimumab, tocilizumab, rituximab, etanercept, and anakinra. There is also a placebo. Straight lines connect the drugs / placebo to each other. One trial compared abatacept with infliximab. Three trials compared abatacept with placebo. Six trials compared infliximab with placebo. Two trials compared golimumab with placebo. Seven trials compared adalimumab with placebo. Four trials compared tocilizumab with placebo. Two trials compared rituximab with placebo. Two trials compared etanercept with placebo. Three trials compared anakinra with placebo.