# Summary of Studies Included in Analyses

Table B-1 Summary of studies included in analyses of response for second-generation antidepressants

Study | N | Duration | Comparison and Dose (mg/day) | Response^a^ | Population
Feighner, 1991^1^ | 123 | 6 weeks | Bupropion 225-450 | 37/61 | Adults
Feighner, 1991^1^ | 123 | 6 weeks | Fluoxetine 20-80 | 35/62 | Adults
Coleman, 2001^2^ | 456 | 8 weeks | Bupropion 150-400 | 76/150 | Adults
Coleman, 2001^2^ | 456 | 8 weeks | Fluoxetine 50-200 | 83/154 | Adults
Coleman, 2001^2^ | 456 | 8 weeks | Placebo | 73/152 | Adults
Weihs, 2000^3^ | 100 | 6 weeks | Bupropion 100-300 | 34/48 | Older adults
Weihs, 2000^3^ | 100 | 6 weeks | Paroxetine 10-40 | 40/52 | Older adults
Rush, 2001^4^ | 248 | 16 weeks | Bupropion 100-300 | 81/122 | Adults
Rush, 2001^4^ | 248 | 16 weeks | Sertraline 50-200 | 93/126 | Adults
Coleman, 1999^5^ | 364 | 8 weeks | Bupropion 150-400 | 78/122 | Adults
Coleman, 1999^5^ | 364 | 8 weeks | Sertraline 50-200 | 66/118 | Adults
Coleman, 1999^5^ | 364 | 8 weeks | Placebo | 66/124 | Adults
Croft, 1999^6^ | 360 | 8 weeks | Bupropion 150-400 | 77/120 | Adults
Croft, 1999^6^ | 360 | 8 weeks | Sertraline 50-200 | 79/119 | Adults
Croft, 1999^6^ | 360 | 8 weeks | Placebo | 55/121 | Adults
Weisler, 1994^7^ | 124 | 6 weeks | Bupropion 225-450 | 33/63 | Adults
Weisler, 1994^7^ | 124 | 6 weeks | Trazodone 150-400 | 21/61 | Adults
Ou, 2011^8^ | 240 | 6 weeks | Citalopram 20-40 | 87/120 | Adults
Ou, 2011^8^ | 240 | 6 weeks | Escitalopram 10-20 | 83/120 | Adults
Haffmans, 1996^9^ | 217 | 6 weeks | Citalopram 20-40 | 33/108 | Adults
Haffmans, 1996^9^ | 217 | 6 weeks | Fluvoxamine 100-200 | 31/109 | Adults
Roose, 2004^10^ | 174 | 8 weeks | Citalopram 10-40 | 34/84 | Older adults
Roose, 2004^10^ | 174 | 8 weeks | Placebo | 34/90 | Older adults
Tourian, 2009^11^ | 638 | 8 weeks | Desvenlafaxine 50-100 | 132/315 | Adults
Tourian, 2009^11^ | 638 | 8 weeks | Duloxetine 60 | 74/159 | Adults
Tourian, 2009^11^ | 638 | 8 weeks | Placebo | 61/164 | Adults
Feiger, 2009^12^ | 244 | 8 weeks | Desvenlafaxine 200-400 | 46/123 | Adults
Feiger, 2009^12^ | 244 | 8 weeks | Placebo | 36/121 | Adults
Boyer, 2008^13^ | 485 | 8 weeks | Desvenlafaxine 50-100 | 205/324 | Adults
Boyer, 2008^13^ | 485 | 8 weeks | Placebo | 40/161 | Adults
Liebowitz, 2007^14^ | 247 | 8 weeks | Desvenlafaxine 100-200 | 52/125 | Adults
Liebowitz, 2007^14^ | 247 | 8 weeks | Placebo | 39/122 | Adults
Septien-Velez, 2007^15^ | 375 | 8 weeks | Desvenlafaxine 200-400 | 142/249 | Adults
Septien-Velez, 2007^15^ | 375 | 8 weeks | Placebo | 48/126 | Adults
Khan, 2007^16^ | 278 | 8 weeks | Duloxetine 60 | 66/138 | Adults
Khan, 2007^16^ | 278 | 8 weeks | Escitalopram 10-20 | 83/140 | Adults
Wade, 2007^17^ | 295 | 24 weeks | Duloxetine 60 | 81/151 | Adults
Wade, 2007^17^ | 295 | 24 weeks | Escitalopram 20 | 94/144 | Adults
Nierenberg,2007.^18^ | 684 | 8 weeks | Duloxetine 40-60 | 117/273 | Adults
Nierenberg,2007.^18^ | 684 | 8 weeks | Escitalopram 10-20 | 112/274 | Adults
Nierenberg,2007.^18^ | 684 | 8 weeks | Placebo | 44/137 | Adults
Goldstein, 2002^19^ | 173 | 8 weeks | Duloxetine 40-120 | 32/70 | Adults
Goldstein, 2002^19^ | 173 | 8 weeks | Fluoxetine 20 | 15/33 | Adults
Goldstein, 2002^19^ | 173 | 8 weeks | Placebo | 24/70 | Adults
Lee, 2007^20^ | 478 | 8 weeks | Duloxetine 60 | 144/238 | Adults
Lee, 2007^20^ | 478 | 8 weeks | Paroxetine 20 | 157/240 | Adults
Detke, 2004^21^ | 367 | 8 weeks | Duloxetine 80-120 | 126/188 | Adults
Detke, 2004^21^ | 367 | 8 weeks | Paroxetine 20 | 63/86 | Adults
Detke, 2004^21^ | 367 | 8 weeks | Placebo | 41/93 | Adults
Perahia, 2006^22^ | 393 | 8 weeks | Duloxetine 80-120 | 129/196 | Adults
Perahia, 2006^22^ | 393 | 8 weeks | Paroxetine 20 | 59/97 | Adults
Perahia, 2006^22^ | 393 | 8 weeks | Placebo | 51/99 | Adults
Brannan, 2005^23^ | 282 | 7 weeks | Duloxetine 60 | 55/141 | Adults
Brannan, 2005^23^ | 282 | 7 weeks | Placebo | 54/141 | Adults
Detke, 2002a24 | 267 | 9 weeks | Duloxetine 60 | 64/128 | Adults
Detke, 2002a24 | 267 | 9 weeks | Placebo | 49/139 | Adults
Detke, 2002b25 | 245 | 9 weeks | Duloxetine 60 | 54/123 | Adults
Detke, 2002b25 | 245 | 9 weeks | Placebo | 26/122 | Adults
Mao, 2008^26^ | 240 | 8 weeks | Escitalopram 10 | 94/123 | Adults
Mao, 2008^26^ | 240 | 8 weeks | Fluoxetine 20 | 89/117 | Adults
Boulenger, 2006^27^ | 459 | 24 weeks | Escitalopram 10-20 | 175/232 | Adults
Boulenger, 2006^27^ | 459 | 24 weeks | Paroxetine 20-40 | 146/227 | Adults
Ventura, 2007^28^ | 215 | 8 weeks | Escitalopram 10 | 75/107 | Adults
Ventura, 2007^28^ | 215 | 8 weeks | Sertraline 50-200 | 74/108 | Adults
Bielski, 2004^29^ | 198 | 8 weeks | Escitalopram 20 | 59/98 | Adults
Bielski, 2004^29^ | 198 | 8 weeks | Venlafaxine 225 | 47/100 | Adults
Hong, 2003^30^ | 132 | 6 weeks | Fluoxetine 20-40 | 30/66 | Adults
Hong, 2003^30^ | 132 | 6 weeks | Mirtazapine 15-45 | 35/66 | Adults
Rush, 1998^31^ | 125 | 8 weeks | Fluoxetine 20-40 | 27/61 | Adults
Rush, 1998^31^ | 125 | 8 weeks | Nefazodone 100-500 | 29/64 | Adults
De Wilde, 1993^32^ | 100 | 6 weeks | Fluoxetine 20-60 | 26/50 | Adults
De Wilde, 1993^32^ | 100 | 6 weeks | Paroxetine 20-40 | 25/50 | Adults
Gagiano, 1993^33^ | 90 | 6 weeks | Fluoxetine 20-60 | 27/45 | Adults
Gagiano, 1993^33^ | 90 | 6 weeks | Paroxetine 20-40 | 30/45 | Adults
Chouinard, 1999^34^ | 203 | 12 weeks | Fluoxetine 20-80 | 67/101 | Adults
Chouinard, 1999^34^ | 203 | 12 weeks | Paroxetine 20-50 | 67/102 | Adults
Fava, 1998^35^ | 128 | 12 weeks | Fluoxetine 20-80 | 31/54 | Adults
Fava, 1998^35^ | 128 | 12 weeks | Paroxetine 20-50 | 32/55 | Adults
Fava, 1998^35^ | 128 | 12 weeks | Placebo | 10/19 | Adults
Fava, 2002^36^ | 284 | 10-16 weeks | Fluoxetine 20-60 | 57/92 | Adults
Fava, 2002^36^ | 284 | 10-16 weeks | Paroxetine 20-60 | 64/96 | Adults
Fava, 2002^36^ | 284 | 10-16 weeks | Sertraline 50-200 | 70/96 | Adults
Wernicke, 1988^37^ | 363 | 6 weeks | Fluoxetine 5-40 | 132/285 | Adults
Wernicke, 1988^37^ | 363 | 6 weeks | Placebo | 18/78 | Adults
Tollefson, 1993^38^ | 671 | 6 weeks | Fluoxetine 20 | 125/335 | Older adults
Tollefson, 1993^38^ | 671 | 6 weeks | Placebo | 92/336 | Older adults
Bennie, 1995^39^ | 286 | 6 weeks | Fluoxetine 20-40 | 63/144 | Adults
Bennie, 1995^39^ | 286 | 6 weeks | Sertraline 50-100 | 73/142 | Adults
Sechter, 1999^40^ | 238 | 24 weeks | Fluoxetine 20-60 | 35/120 | Adults
Sechter, 1999^40^ | 238 | 24 weeks | Sertraline 50-150 | 48/118 | Adults
Newhouse, 2005^41^ | 236 | 12 weeks | Fluoxetine 20-40 | 84/119 | Older adults
Newhouse, 2005^41^ | 236 | 12 weeks | Sertraline 50-100 | 85/117 | Older adults
Dierick, 1996^42^ | 314 | 8 weeks | Fluoxetine 20 | 95/161 | Adults
Dierick, 1996^42^ | 314 | 8 weeks | Venlafaxine 75-150 | 107/153 | Adults
Tylee, 1997^43^ | 341 | 12 weeks | Fluoxetine 20 | 98/170 | Adults
Tylee, 1997^43^ | 341 | 12 weeks | Venlafaxine 75 | 81/171 | Adults
Costa e Silva, 1998^44^ | 382 | 8 weeks | Fluoxetine 20-40 | 153/186 | Adults
Costa e Silva, 1998^44^ | 382 | 8 weeks | Venlafaxine 75-150 | 170/196 | Adults
Alves, 1999^45^ | 87 | 12 weeks | Fluoxetine 20-40 | 35/47 | Adults
Alves, 1999^45^ | 87 | 12 weeks | Venlafaxine 75-150 | 35/40 | Adults
Tzanakaki, 2000^46^ | 109 | 6 weeks | Fluoxetine 20-60 | 31/54 | Adults
Tzanakaki, 2000^46^ | 109 | 6 weeks | Venlafaxine 75-250 | 36/55 | Adults
De Nayer, 2002^47^ | 146 | 12 weeks | Fluoxetine 20 | 34/73 | Adults
De Nayer, 2002^47^ | 146 | 12 weeks | Venlafaxine 75 | 48/73 | Adults
Rudolph, 1999^48^ | 301 | 8 weeks | Fluoxetine 20-60 | 52/103 | Adults
Rudolph, 1999^48^ | 301 | 8 weeks | Venlafaxine 75-225 | 54/100 | Adults
Rudolph, 1999^48^ | 301 | 8 weeks | Placebo | 41/98 | Adults
Nemeroff, 2007^49^ | 308 | 6 weeks | Fluoxetine 20-60 | 45/104 | Adults
Nemeroff, 2007^49^ | 308 | 6 weeks | Venlafaxine 75-225 | 51/102 | Adults
Nemeroff, 2007^49^ | 308 | 6 weeks | Placebo | 37/102 | Adults
Lydiard, 1989^50^ | 36 | 6 weeks | Fluvoxamine 100-300 | 9/18 | Adults
Lydiard, 1989^50^ | 36 | 6 weeks | Placebo | 5/18 | Adults
Rossini, 2005^51^ | 88 | 7 weeks | Fluvoxamine 200 | 28/40 | Older adults
Rossini, 2005^51^ | 88 | 7 weeks | Sertraline 150 | 25/48 | Older adults
Benkert, 2000^52^ | 275 | 6 weeks | Mirtazapine 20-40 | 74/139 | Adults
Benkert, 2000^52^ | 275 | 6 weeks | Paroxetine 15-45 | 66/136 | Adults
Halikas, 1995^53^ | 150 | 6 weeks | Mirtazapine 5-35 | 20/50 | Older adults
Halikas, 1995^53^ | 150 | 6 weeks | Trazodone 40-280 | 17/50 | Older adults
Halikas, 1995^53^ | 150 | 6 weeks | Placebo | 25/50 | Older adults
van Moffaert, 1995^54^ | 200 | 6 weeks | Mirtazapine 24-72 | 61/100 | Adults
van Moffaert, 1995^54^ | 200 | 6 weeks | Trazodone 150-450 | 51/100 | Adults
Hicks, 2002^55^ | 40 | 8 weeks | Nefazodone 400-600 | 11/20 | Adults
Hicks, 2002^55^ | 40 | 8 weeks | Paroxetine 20-40 | 16/20 | Adults
Cohn, 1996^56^ | 81 | 8 weeks | Nefazodone 200-600 | 25/39 | Adults
Cohn, 1996^56^ | 81 | 8 weeks | Placebo | 15/42 | Adults
Fontaine, 1994^57^ | 135 | 6 weeks | Nefazodone 100-500 | 41/90 | Adults
Fontaine, 1994^57^ | 135 | 6 weeks | Placebo | 14/45 | Adults
Feiger, 1996^58^ | 160 | 6 weeks | Nefazodone 100-600 | 42/78 | Adults
Feiger, 1996^58^ | 160 | 6 weeks | Sertraline 50-200 | 41/82 | Adults
Rickels, 1989^59^ | 111 | 6 weeks | Paroxetine 10-50 | 24/55 | Adults
Rickels, 1989^59^ | 111 | 6 weeks | Placebo | 12/56 | Adults
Rapaport, 2009^60^ | 525 | 10 weeks | Paroxetine 12.5-25 | 185/345 | Older adults
Rapaport, 2009^60^ | 525 | 10 weeks | Placebo | 72/180 | Older adults
Kasper, 2005^61^ | 108 | 6 weeks | Paroxetine 20-40 | 48/53 | Adults
Kasper, 2005^61^ | 108 | 6 weeks | Trazodone 150-450 | 48/55 | Adults
Reimherr, 1990^62^ | 299 | 8 weeks | Sertraline 20-200 | 77/149 | Adults
Reimherr, 1990^62^ | 299 | 8 weeks | Placebo | 49/150 | Adults
Lydiard, 1997^63^ | 261 | 8 weeks | Sertraline 50-200 | 65/132 | Adults
Lydiard, 1997^63^ | 261 | 8 weeks | Placebo | 43/129 | Adults
Olie, 1997^64^ | 258 | 6 weeks | Sertraline 50-200 | 70/129 | Adults
Olie, 1997^64^ | 258 | 6 weeks | Placebo | 45/129 | Adults
Hypericum Group, 2002^65^ | 227 | 8 weeks | Sertraline 50-100 | 26/111 | Adults
Hypericum Group, 2002^65^ | 227 | 8 weeks | Placebo | 13/116 | Adults
Schneider, 2003^66^ | 747 | 8 weeks | Sertraline 50-100 | 126/371 | Older adults
Schneider, 2003^66^ | 747 | 8 weeks | Placebo | 96/376 | Older adults
Blumenthal, 2007^67^ | 98 | 16 weeks | Sertraline 50-200 | 19/49 | Adults
Blumenthal, 2007^67^ | 98 | 16 weeks | Placebo | 16/49 | Adults
Munizza, 2006^68^ | 122 | 6 weeks | Sertraline 50-100 | 37/60 | Adults
Munizza, 2006^68^ | 122 | 6 weeks | Trazodone 150-450 | 46/62 | Adults
Mehtonen, 2000^69^ | 147 | 8 weeks | Sertraline 50-100 | 41/72 | Adults
Mehtonen, 2000^69^ | 147 | 8 weeks | Venlafaxine 75-150 | 49/75 | Adults
Sir, 2005^70^ | 163 | 8 weeks | Sertraline 50-150 | 56/79 | Adults
Sir, 2005^70^ | 163 | 8 weeks | Venlafaxine 75-225 | 56/84 | Adults
Shelton, 2006^71^ | 160 | 8 weeks | Sertraline 50-150 | 45/82 | Adults
Shelton, 2006^71^ | 160 | 8 weeks | Venlafaxine 75-225 | 49/78 | Adults
Thase, 1997^72^ | 197 | 8 weeks | Venlafaxine 75-225 | 53/95 | Adults
Thase, 1997^72^ | 197 | 8 weeks | Placebo | 29/102 | Adults

Note: Studies are listed alphabetically by drug and chronologically within each set of drugs

a Response, defined as a 50% improvement on the Hamilton Depression Rating Scale (HAM-D), is presented as the number of responders out of the number in the group.

Abbreviations: mg = milligram

Table B-2 Summary of studies included in analyses of mean change in HAM-D for second-generation antidepressants

Study | N | Duration | Comparison and Dose (mg/day) | Mean change in HAM-D (SE)
Rush, 2001^4^ | 248 | 16 weeks | Bupropion 100-300 | -15.5 (0.66)
Rush, 2001^4^ | 248 | 16 weeks | Sertraline 50-200 | -16.3 (0.69)
Ou, 2011^8^ | 232 | 6 weeks | Citalopram 20-40 | -13.8 (0.69)
Ou, 2011^8^ | 232 | 6 weeks | Escitalopram 10-20 | -14.7 (0.76)
Septien-Velez, 2007^15^ | 245 | 8 weeks | Desvenlafaxine 200-400 | -12.6 (0.75)
Septien-Velez, 2007^15^ | 245 | 8 weeks | Placebo | -9.3 (0.74)
Boyer, 2008^13^ | 325 | 8 weeks | Desvenlafaxine 50-100 | -13.2 (0.82)
Boyer, 2008^13^ | 325 | 8 weeks | Placebo | -10.7 (0.84)
Feiger, 2009^12^ | 235 | 8 weeks | Desvenlafaxine 200-400 | -9.1 (0.67)
Feiger, 2009^12^ | 235 | 8 weeks | Placebo | -7.5 (0.66)
Khan, 2007^16^ | 262 | 8 weeks | Duloxetine 60 | -9.6 (0.68)
Khan, 2007^16^ | 262 | 8 weeks | Escitalopram10-20 | -11.1 (0.59)
Nierenberg, 2007^18^ | 684 | 8 weeks | Duloxetine 60 | -7.61 (0.42)
Nierenberg, 2007^18^ | 684 | 8 weeks | Escitalopram 10 | -7.22 (0.40)
Nierenberg, 2007^18^ | 684 | 8 weeks | Placebo | -5.97 (0.58)
Detke, 2004^21^ | 272 | 8 weeks | Duloxetine 80-120 | -12.1 (0.50)
Detke, 2004^21^ | 272 | 8 weeks | Paroxetine 20 | -11.7 (0.50)
Detke, 2004^21^ | 272 | 8 weeks | Placebo | -8.8 (0.50)
Perahia, 2006^22^ | 289 | 8 weeks | Duloxetine 80-120 | -12.1 (0.50)
Perahia, 2006^22^ | 289 | 8 weeks | Paroxetine 20 | -11.7 (0.50)
Perahia, 2006^22^ | 289 | 8 weeks | Placebo | -8.8 (0.50)
Brannan, 2005^23^ | 268 | 7 weeks | Duloxetine 60 | -10.85 (0.69)
Brannan, 2005^23^ | 268 | 7 weeks | Placebo | -10.27 (0.67)
Mao, 2008^26^ | 231 | 8 weeks | Escitalopram 10 | -15.8 (0.59)
Mao, 2008^26^ | 231 | 8 weeks | Fluoxetine 20 | -14.7 (0.74)
Ventura, 2007^28^ | 211 | 8 weeks | Escitalopram 10 | -16.9 (0.70)
Ventura, 2007^28^ | 211 | 8 weeks | Sertraline 50-200 | -16.1 (0.80)
Bielski, 2004^29^ | 195 | 8 weeks | Escitalopram 20 | -14.9 (0.91)
Bielski, 2004^29^ | 195 | 8 weeks | Venlafaxine 225 | -12.9 (0.92)
Rush, 1998^31^ | 122 | 8 weeks | Fluoxetine 20-40 | -12.2 (0.79)
Rush, 1998^31^ | 122 | 8 weeks | Nefazodone 200-500 | -11.4 (0.83)
De Wilde, 1993^32^ | 78 | 6 weeks | Fluoxetine 20-60 | -15.0 (1.61)
De Wilde, 1993^32^ | 78 | 6 weeks | Paroxetine 20-40 | -17.3 (1.56)
Chouinard, 1999^34^ | 198 | 12 weeks | Fluoxetine 20-80 | -14.8 (0.11)
Chouinard, 1999^34^ | 198 | 12 weeks | Paroxetine 20-50 | -13.9 (0.11)
Fava, 1998^35^ | 128 | 12 weeks | Fluoxetine 20-80 | -10.8 (1.29)
Fava, 1998^35^ | 128 | 12 weeks | Paroxetine 20-50 | -11.1 (1.27)
Fava, 1998^35^ | 128 | 12 weeks | Placebo | -11.6 (2.04)
Wernicke, 1988^37^ | 169 | 6 weeks | Fluoxetine 5-40 | -11.2 (0.86)
Wernicke, 1988^37^ | 169 | 6 weeks | Placebo | -7.0 (0.98)
Tollefson, 1993^38^ | 534 | 6 weeks | Fluoxetine 20 | -10.3 (0.49)
Tollefson, 1993^38^ | 534 | 6 weeks | Placebo | -7.9 (0.44)
Perry, 1989^73^ | 40 | 6 weeks | Fluoxetine 21-50 | -14.8 (1.74)
Perry, 1989^73^ | 40 | 6 weeks | Trazodone 241-337 | -17.1 (1.02)
Beasley, 1991^74^ | 120 | 6 weeks | Fluoxetine 20-40 | -12.2 (0.91)
Beasley, 1991^74^ | 120 | 6 weeks | Trazodone 50-400 | -13.9 (1.02)
Dierick, 1996^42^ | 314 | 8 weeks | Fluoxetine 20 | -14.4 (0.88)
Dierick, 1996^42^ | 314 | 8 weeks | Venlafaxine 75-150 | -16.1 (0.70)
De Nayer, 2002^47^ | 131 | 12 weeks | Fluoxetine 20 | -10.4 (1.05)
De Nayer, 2002^47^ | 131 | 12 weeks | Venlafaxine 75 | -14.4 (0.95)
Kiev, 1997^75^ | 58 | 7 weeks | Fluvoxamine 50 | -13.5 (1.3)
Kiev, 1997^75^ | 58 | 7 weeks | Paroxetine 20 | -12.9 (1.3)
Ushiroyama, 2004^76^ | 105 | 12 weeks | Fluvoxamine 50 | -15.9 (0.66)
Ushiroyama, 2004^76^ | 105 | 12 weeks | Paroxetine 20 | -13.9 (0.66)
Nemeroff, 1995^77^ | 92 | 7 weeks | Fluvoxamine 50-150 | -10.6 (1.11)
Nemeroff, 1995^77^ | 92 | 7 weeks | Sertraline 50-200 | -11.0 (0.90)
Rossini, 2005^51^ | 84 | 7 weeks | Fluvoxamine 50-200 | -23.7 (1.72)
Rossini, 2005^51^ | 84 | 7 weeks | Sertraline 25-150 | -18.0 (1.50)
Schatzberg, 2002^78^ | 246 | 8 weeks | Mirtazapine 15-45 | -9.2 (0.51)
Schatzberg, 2002^78^ | 246 | 8 weeks | Paroxetine 20-40 | -7.3 (0.54)
Ehde, 2008^79^ | 42 | 12 weeks | Paroxetine 10-40 | -7.8 (1.13)
Ehde, 2008^79^ | 42 | 12 weeks | Placebo | -7.6 (1.20)
Kasper, 2005^61^ | 108 | 6 weeks | Paroxetine 20-40 | -15.0 (0.68)
Kasper, 2005^61^ | 108 | 6 weeks | Trazodone 150-450 | -14.6 (0.66)
McPartlin, 1998^80^ | 336 | 12 weeks | Paroxetine 20 | -14.1 (0.60)
McPartlin, 1998^80^ | 336 | 12 weeks | Venlafaxine 75 | -14.7 (0.57)
Ballus, 2000^81^ | 84 | 24 weeks | Paroxetine 20-40 | -15.5 (0.95)
Ballus, 2000^81^ | 84 | 24 weeks | Venlafaxine 75-150 | -15.7 (0.90)
Reimherr, 1990^62^ | 283 | 8 weeks | Sertraline 50-200 | -11.7 (0.69)
Reimherr, 1990^62^ | 283 | 8 weeks | Placebo | -8.2 (0.66)
Lydiard, 1997^63^ | 234 | 8 weeks | Sertraline 50-200 | -11.1 (0.63)
Lydiard, 1997^63^ | 234 | 8 weeks | Placebo | -8.8 (0.65)
Hypericum, 2002^65^ | 225 | 8 weeks | Sertraline 50-100 | -10.5 (0.72)
Hypericum, 2002^65^ | 225 | 8 weeks | Placebo | -9.2 (0.67)
Blumenthal, 2007^67^ | 98 | 16 weeks | Sertraline 50-200 | -6.1 (0.96)
Blumenthal, 2007^67^ | 98 | 16 weeks | Placebo | -6.1 (1.04)
Munizza, 2006^68^ | 121 | 6 weeks | Sertraline 50-100 | -11.5 (1.08)
Munizza, 2006^68^ | 121 | 6 weeks | Trazodone 150-450 | -12.9 (1.15)
Sir, 2005^70^ | 158 | 8 weeks | Sertraline 50-150 | -15.9 (0.95)
Sir, 2005^70^ | 158 | 8 weeks | Venlafaxine 75-225 | -14.3 (0.94)
Shelton, 2006^71^ | 158 | 8 weeks | Sertraline 50-150 | -11.3 (0.61)
Shelton, 2006^71^ | 158 | 8 weeks | Venlafaxine 75-225 | -12.7 (0.64)
Thase, 1997^72^ | 191 | 8 weeks | Venlafaxine 75-225 | -11.7 (0.75)
Thase, 1997^72^ | 191 | 8 weeks | Placebo | -7.3 (0.71)

Note: studies are listed alphabetically by drug and chronologically within each set of drugs

Abbreviations: mg = milligram; SE = standard error

Table B-3 Summary of studies included in analyses of ACR50 response for biologic DMARDs

Author, Year Study Name | N | Comparison and Dose | Disease Duration (yrs) | Response^a^
Kremer, 2003^82^ NR | 234 | Abatacept 10 mg/kg | 9.7 | 42/115
Kremer, 2003^82^ NR | 234 | Placebo | 8.9 | 14/119
Kremer, 2006^83^ AIM | 652 | Abatacept 10 mg/kg | 8.5 | 169/433
Kremer, 2006^83^ AIM | 652 | Placebo | 8.9 | 36/219
Schiff, 2008^84^ ATTEST | 431 | Abatacept 10 mg/kg | 7.9 | 63/156
Schiff, 2008^84^ ATTEST | 431 | Infliximab 3 mg/kg | 7.3 | 61/165
Schiff, 2008^84^ ATTEST | 431 | Placebo | 8.4 | 22/110
Furst, 2003^85^ STAR | 636 | Adalimumab 40 mg | 9.3 | 92/318
Furst, 2003^85^ STAR | 636 | Placebo | 11.5 | 36/318
van de Putte, 2003^86^ NR | 212 | Adalimumab 20 mg, 40 mg | 10.2 | 36/142
van de Putte, 2003^86^ NR | 212 | Placebo | 9.4 | 1/70
Weinblatt, 2003^87^ ARMADA | 129 | Adalimumab 40 mg | 12.2 | 37/67
Weinblatt, 2003^87^ ARMADA | 129 | Placebo | 11.1 | 5/62
Keystone, 2004^88^ NR | 619 | Adalimumab 20 mg, 40 mg | 11.0 | 166/419
Keystone, 2004^88^ NR | 619 | Placebo | 10.9 | 19/200
van de Putte, 2004^89^ NR | 438 | Adalimumab 20 mg, 40 mg | 10.8 | 84/328
van de Putte, 2004^89^ NR | 438 | Placebo | 11.6 | 9/110
Kim, 2007^90^ NR | 128 | Adalimumab 40 mg | 6.8 | 28/65
Kim, 2007^90^ NR | 128 | Placebo | 6.9 | 9/63
Chen, 2009^91^ NR | 47 | Adalimumab 40 mg | 6.2 | 12/35
Chen, 2009^91^ NR | 47 | Placebo | 8.3 | 2/12
Bresnihan, 1998^92^ NR | 353 | Anakinra 75 mg, 150 mg | 4.1 | 33/232
Bresnihan, 1998^92^ NR | 353 | Placebo | 3.7 | 9/121
Cohen, 2002^93^ NR | 153 | Anakinra 1 mg/kg, 2 mg/kg | 7.3 | 22/105
Cohen, 2002^93^ NR | 153 | Placebo | 7.8 | 2/48
Cohen, 2004^94^ NR | 506 | Anakinra 100 mg | 11.0 | 43/253
Cohen, 2004^94^ NR | 506 | Placebo | 10.0 | 20/253
Moreland, 1997^95^ NR | 88 | Etanercept 16 m/m sq. | NR | 25/44
Moreland, 1997^95^ NR | 88 | Placebo | NR | 3/44
Moreland, 1999^96^ NR | 158 | Etanercept 25 mg | 12 | 31/78
Moreland, 1999^96^ NR | 158 | Placebo | 12 | 4/80
Weinblatt, 1999^97^ NR | 89 | Etanercept 25 mg | 13 | 23/59
Weinblatt, 1999^97^ NR | 89 | Placebo | 13 | 1/30
Lan, 2004^98^ NR | 58 | Etanercept 25 mg | NR | 19/29
Lan, 2004^98^ NR | 58 | Placebo | NR | 3/29
Kay, 2008^99^ NR | 70 | Golimumab 50 mg | 8.2 | 13/35
Kay, 2008^99^ NR | 70 | Placebo | 5.6 | 2/35
Keystone, 2009^100^ GO-FORWARD | 222 | Golimumab 50 mg | 4.5 | 31/89
Keystone, 2009^100^ GO-FORWARD | 222 | Placebo | 6.5 | 13/133
Maini, 1999^101^ ATTRACT | 428 | Infliximab 3 mg/kg, 10 mg/kg | 8.3 | 94/340
Maini, 1999^101^ ATTRACT | 428 | Placebo | 8.9 | 4/88
Kavanaugh, 2000^102^ NR | 21 | Infliximab 5 mg/kg, 10 mg/kg | 6.6 | 3/14
Kavanaugh, 2000^102^ NR | 21 | Placebo | 4.9 | 1/7
Abe, 2006^103^ NR | 147 | Infliximab 3 mg/kg, 10 mg/kg | 8.1 | 33/100
Abe, 2006^103^ NR | 147 | Placebo | 7.5 | 4/47
Westhovens, 2006^104^ START | 1,084 | Infliximab 3 mg/kg, 10 mg/kg | 7.1 | 229/721
Westhovens, 2006^104^ START | 1,084 | Placebo | 8.4 | 33/363
Zhang, 2006^105^ NR | 173 | Infliximab 3 mg/kg | 7.1 | 38/87
Zhang, 2006^105^ NR | 173 | Placebo | 8.0 | 22/86
Edwards, 2004^106^ NR | 80 | Rituximab 2×1,000 mg | 12 | 17/40
Edwards, 2004^106^ NR | 80 | Placebo | 11 | 5/40
Emery, 2010^107^ SERENE | 275 | Rituximab 2×500 mg, 2×1,000 mg | 6.9 | 88/340
Emery, 2010^107^ SERENE | 275 | Placebo | 7.5 | 16/172
Maini, 2006^108^ CHARISMA | 148 | Tocilizumab 4 mg/kg, 8 mg/kg | 0.79 | 45/99
Maini, 2006^108^ CHARISMA | 148 | Placebo | 0.94 | 14/49
Genovese, 2008^109^ TOWARD | 1,220 | Tocilizumab 8 mg/kg | 9.8 | 302/805
Genovese, 2008^109^ TOWARD | 1,220 | Placebo | 9.8 | 37/415
Smolen, 2008^110^ OPTION | 623 | Tocilizumab 4 mg/kg, 8 mg/kg | 7.5 | 157/419
Smolen, 2008^110^ OPTION | 623 | Placebo | 7.8 | 22/204
Kremer, 2011^111^ LITHE | 1,196 | Tocilizumab 4 mg/kg, 8 mg/kg | 9.4 | 228/802
Kremer, 2011^111^ LITHE | 1,196 | Placebo | 9.0 | 38/394

Note: studies are listed alphabetically by drug and chronologically within each set of drugs

a Response is presented as the number of responders/total number in the group.

Abbreviations: kg = kilogram; mg = milligram; NR = not reported; yrs = years

## References

1 Feighner JP, Gardner EA, Johnston JA, et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry. Aug. 1991;52(8):329-35. [pmid: 1907963].
2 Coleman CC, King BR, Bolden-Watson C, et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther. Jul. 2001;23(7):1040-58. [pmid: 11519769].
3 Weihs KL, Settle EC Jr., Batey SR, et al. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry. Mar. 2000;61(3):196-202. [pmid: 10817105].
4 Rush AJ, Trivedi MH, Carmody TJ, et al. Response in relation to baseline anxiety levels in major depressive disorder treated with bupropion sustained release or sertraline. Neuropsychopharmacology. Jul. 2001;25(1):131-8. [pmid: 11377926].
5 Coleman CC, Cunningham LA, Foster VJ, et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry. Dec. 1999;11(4):205-15. [pmid: 10596735].
6 Croft H, Settle E Jr., Houser T, et al. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther. Apr. 1999;21(4):643-58. [pmid: 10363731].
7 Weisler RH, Johnston JA, Lineberry CG, et al. Comparison of bupropion and trazodone for the treatment of major depression. J Clin Psychopharmacol. Jun. 1994;14(3):170-9. [pmid: 8027413].
8 Ou JJ, Xun GL, Wu RR, et al. Efficacy and safety of escitalopram versus citalopram in major depressive disorder: a 6-week, multicenter, randomized, double-blind, flexible-dose study. Psychopharmacology (Berl). Feb. 2011;213(2-3):639-46. [pmid: 20340011].
9 Haffmans PM, Timmerman L, Hoogduin CA. Efficacy and tolerability of citalopram in comparison with fluvoxamine in depressed outpatients: a double-blind, multicentre study. The LUCIFER Group. Int Clin Psychopharmacol. Sep. 1996;11(3):157-64. [pmid: 8923094].
10 Roose SP, Sackeim HA, Krishnan KR, et al. Antidepressant pharmacotherapy in the treatment of depression in the very old: a randomized, placebo-controlled trial. Am J Psychiatry. Nov. 2004;161(11):2050-9. [pmid: 15514406].
11 Tourian KA, Padmanabhan SK, Groark J, et al. Desvenlafaxine 50 and 100 mg/d in the treatment of major depressive disorder: an 8-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group trial and a post hoc pooled analysis of three studies. Clin Ther. 2009:1405-23. [pmid: 19698901].
12 Feiger AD, Tourian KA, Rosas GR, et al. A placebo-controlled study evaluating the efficacy and safety of flexible-dose desvenlafaxine treatment in outpatients with major depressive disorder. CNS Spectr. 2009:41-50. [pmid: 19169187].
13 Boyer P, Montgomery S, Lepola U, et al. Efficacy, safety, and tolerability of fixed-dose desvenlafaxine 50 and 100 mg/day for major depressive disorder in a placebo-controlled trial. Int Clin Psychopharmacol. 2008:243-53. [pmid: 18703933].
14 Liebowitz MR, Yeung PP, Entsuah R. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in adult outpatients with major depressive disorder. J Clin Psychiatry. 2007:1663-72. [pmid: 18052559].
15 Septien-Velez L, Pitrosky B, Padmanabhan SK, et al. A randomized, double-blind, placebo-controlled trial of desvenlafaxine succinate in the treatment of major depressive disorder. Int Clin Psychopharmacol. 2007:338-47. [pmid: 17917552].
16 Khan A, Bose A, Alexopoulos GS, et al. Double-blind comparison of escitalopram and duloxetine in the acute treatment of major depressive disorder. Clin Drug Investig. 2007:481-92.
17 Wade A, Gembert K, Florea I. A comparative study of the efficacy of acute and continuation treatment with escitalopram versus duloxetine in patients with major depressive disorder. Curr Med Res Opin. 2007:1605-14. [pmid: 17559755].
18 Nierenberg AA, Greist JH, Mallinckrodt CH, et al. Duloxetine versus escitalopram and placebo in the treatment of patients with major depressive disorder: onset of antidepressant action, a non-inferiority study. Curr Med Res Opin. 2007:401-16. [pmid: 17288694].
19 Goldstein DJ, Mallinckrodt C, Lu Y, et al. Duloxetine in the treatment of major depressive disorder: a double-blind clinical trial. J Clin Psychiatry. Mar. 2002;63(3):225-31. [pmid: 11926722].
20 Lee P, Shu L, Xu X, et al. Once-daily duloxetine 60 mg in the treatment of major depressive disorder: multicenter, double-blind, randomized, paroxetine-controlled, non-inferiority trial in China, Korea, Taiwan and Brazil. Psychiatry Clin Neurosci. 2007:295-307. [pmid: 17472599].
21 Detke MJ, Wiltse CG, Mallinckrodt CH, et al. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Neuropsychopharmacol. Dec. 2004;14(6):457-70. [pmid: 15589385].
22 Perahia DG, Wang F, Mallinckrodt CH, et al. Duloxetine in the treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. Eur Psychiatry. 2006:367-78. [pmid: 16697153].
23 Brannan SK, Mallinckrodt CH, Brown EB, et al. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res. Jan. 2005;39(1):43-53. [pmid: 15504423].
24 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine 60 mg once daily dosing versus placebo in the acute treatment of major depression. J Psychiatr Res. Nov-Dec. 2002;36(6):383-90. [pmid: 12393307].
25 Detke MJ, Lu Y, Goldstein DJ, et al. Duloxetine, 60 mg once daily, for major depressive disorder: a randomized double-blind placebo-controlled trial. J Clin Psychiatry. Apr. 2002;63(4):308-15. [pmid: 12000204].
26 Mao PX, Tang YL, Jiang F, et al. Escitalopram in major depressive disorder: a multicenter, randomized, double-blind, fixed-dose, parallel trial in a Chinese population. Depress Anxiety. 2008:46-54. [pmid: 17149753].
27 Boulenger JP, Huusom AK, Florea I, et al. A comparative study of the efficacy of long-term treatment with escitalopram and paroxetine in severely depressed patients. Curr Med Res Opin. 2006:1331-41. [pmid: 16834832].
28 Ventura D, Armstrong EP, Skrepnek GH, et al. Escitalopram versus sertraline in the treatment of major depressive disorder: a randomized clinical trial. Curr Med Res Opin. 2007:245-50. [pmid: 17288677].
29 Bielski RJ, Ventura D, Chang CC. A double-blind comparison of escitalopram and venlafaxine extended release in the treatment of major depressive disorder. J Clin Psychiatry. Sep. 2004;65(9):1190-6. [pmid: 15367045].
30 Hong CJ, Hu WH, Chen CC, et al. A double-blind, randomized, group-comparative study of the tolerability and efficacy of 6 weeks' treatment with mirtazapine or fluoxetine in depressed Chinese patients. J Clin Psychiatry. Aug. 2003;64(8):921-6. [pmid: 12927007].
31 Rush AJ, Armitage R, Gillin JC, et al. Comparative effects of nefazodone and fluoxetine on sleep in outpatients with major depressive disorder. Biol Psychiatry. Jul. 1. 1998;44(1):3-14. [pmid: 9646878].
32 De Wilde J, Spiers R, Mertens C, et al. A double-blind, comparative, multicentre study comparing paroxetine with fluoxetine in depressed patients. Acta Psychiatr Scand. Feb. 1993;87(2):141-5. [pmid: 8447241].
33 Gagiano CA. A double blind comparison of paroxetine and fluoxetine in patients with major depression. Br J Clin Res. 1993;4:145-52.
34 Chouinard G, Saxena B, Belanger MC, et al. A Canadian multicenter, double-blind study of paroxetine and fluoxetine in major depressive disorder. J Affect Disord. Jul. 1999;54(1-2):39-48. [pmid: 10403145].
35 Fava M, Amsterdam JD, Deltito JA, et al. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry. Dec. 1998;10(4):145-50. [pmid: 9988054].
36 Fava M, Hoog SL, Judge RA, et al. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol. Apr. 2002;22(2):137-47. [pmid: 11910258].
37 Wernicke JF, Dunlop SR, Dornseif BE, et al. Low-dose fluoxetine therapy for depression. Psychopharmacol Bull. 1988;24(1):183-8. [pmid: 3290940].
38 Tollefson GD, Holman SL. Analysis of the Hamilton Depression Rating Scale factors from a double-blind, placebo-controlled trial of fluoxetine in geriatric major depression. Int Clin Psychopharmacol. Winter. 1993;8(4):253-9. [pmid: 8277144].
39 Bennie EH, Mullin JM, Martindale JJ. A double-blind multicenter trial comparing sertraline and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jun. 1995;56(6):229-37. [pmid: 7775364].
40 Sechter D, Troy S, Paternetti S, et al. A double-blind comparison of sertraline and fluoxetine in the treatment of major depressive episode in outpatients. Eur Psychiatry. Mar. 1999;14(1):41-8. [pmid: 10572324].
41 Newhouse PA, Krishnan KR, Doraiswamy PM, et al. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. J Clin Psychiatry. Aug. 2000;61(8):559-68. [pmid: 10982198].
42 Dierick M, Ravizza L, Realini R, et al. A double-blind comparison of venlafaxine and fluoxetine for treatment of major depression in outpatients. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1996;20(1):57-71. [pmid: 8861177].
43 Tylee A, Beaumont G, Bowden MW, et al. A double-blind, randomized, 12-week comparison study of the safety and efficacy of venlafaxine and fluoxetine in moderate to severe major depression in general practice. Primary Care Psychiatry. 1997;3(1):51-8.
44 Costa e Silva J. Randomized, double-blind comparison of venlafaxine and fluoxetine in outpatients with major depression. J Clin Psychiatry. Jul. 1998;59(7):352-7. [pmid: 9714263].
45 Alves C, Cachola I, Brandao J. Efficacy and tolerability of venlafaxine and fluoxetine in outpatients with major depression. Primary Care Psychiatry. 1999;5(2):57-63.
46 Tzanakaki M, Guazzelli M, Nimatoudis I, et al. Increased remission rates with venlafaxine compared with fluoxetine in hospitalized patients with major depression and melancholia. Int Clin Psychopharmacol. 2000:29-34. [pmid: 10836283].
47 De Nayer A, Geerts S, Ruelens L, et al. Venlafaxine compared with fluoxetine in outpatients with depression and concomitant anxiety. Int J Neuropsychopharmacol. Jun. 2002;5(2):115-20. [pmid: 12135535].
48 Rudolph RL, Feiger AD. A double-blind, randomized, placebo-controlled trial of once-daily venlafaxine extended release (XR) and fluoxetine for the treatment of depression. J Affect Disord. Dec. 1999;56(2-3):171-81. [pmid: 10701474].
49 Nemeroff CB, Thase ME. A double-blind, placebo-controlled comparison of venlafaxine and fluoxetine treatment in depressed outpatients. J Psychiatr Res. 2007:351-9. Epub 2005 Sep 12. [pmid: 16165158].
50 Lydiard RB, Laird LK, Morton WA Jr., et al. Fluvoxamine, imipramine, and placebo in the treatment of depressed outpatients: effects on depression. Psychopharmacol Bull. 1989;25(1):68-70. [pmid: 2505304].
51 Rossini D, Serretti A, Franchini L, et al. Sertraline versus fluvoxamine in the treatment of elderly patients with major depression: a double-blind, randomized trial. J Clin Psychopharmacol. Oct. 2005;25(5):471-5. [pmid: 16160624].
52 Benkert O, Szegedi A, Kohnen R. Mirtazapine compared with paroxetine in major depression. J Clin Psychiatry. Sep. 2000;61(9):656-63. [pmid: 11030486].
53 Halikas JA. Org 3770 (mirtazapine) versus trazodone: A placebo controlled trial in depressed elderly patients. Hum Psychopharmacol. 1995;10(Suppl 2):S125-S33.
54 van Moffaert M, de Wilde J, Vereecken A, et al. Mirtazapine is more effective than trazodone: a double-blind controlled study in hospitalized patients with major depression. Int Clin Psychopharmacol. Mar. 1995;10(1):3-9. [pmid: 7622801].
55 Hicks JA, Argyropoulos SV, Rich AS, et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in out-patients with depression. Br J Psychiatry. Jun. 2002;180:528-35. [pmid: 12042232].
56 Cohn CK, Robinson DS, Roberts DL, et al. Responders to antidepressant drug treatment: a study comparing nefazodone, imipramine, and placebo in patients with major depression. J Clin Psychiatry. Suppl 2. 1996;57:15-8. [pmid: 8626358].
57 Fontaine R, Ontiveros A, Elie R, et al. A double-blind comparison of nefazodone, imipramine, and placebo in major depression. J Clin Psychiatry. Jun. 1994;55(6):234-41. [pmid: 8071277].
58 Feiger A, Kiev A, Shrivastava RK, et al. Nefazodone versus sertraline in outpatients with major depression: focus on efficacy, tolerability, and effects on sexual function and satisfaction. J Clin Psychiatry. Suppl 2. 1996;57:53-62. [pmid: 8626364].
59 Rickels K, Amsterdam J, Clary C, et al. A placebo-controlled, double-blind, clinical trial of paroxetine in depressed outpatients. Acta Psychiatr Scand Suppl. 1989;350:117-23. [pmid: 2530761].
60 Rapaport MH, Lydiard RB, Pitts CD, et al. Low doses of controlled-release paroxetine in the treatment of late-life depression: a randomized, placebo-controlled trial. J Clin Psychiatry. 2009:46-57. [pmid: 19026248].
61 Kasper S, Olivieri L, Di Loreto G, et al. A comparative, randomised, double-blind study of trazodone prolonged-release and paroxetine in the treatment of patients with major depressive disorder. Curr Med Res Opin. Aug. 2005;21(8):1139-46. [pmid: 16083521].
62 Reimherr FW, Chouinard G, Cohn CK, et al. Antidepressant efficacy of sertraline: a double-blind, placebo- and amitriptyline-controlled, multicenter comparison study in outpatients with major depression. J Clin Psychiatry. Dec. Suppl B. 1990;51:18-27. [pmid: 2258378].
63 Lydiard RB, Stahl SM, Hertzman M, et al. A double-blind, placebo-controlled study comparing the effects of sertraline versus amitriptyline in the treatment of major depression. J Clin Psychiatry. Nov. 1997;58(11):484-91. [pmid: 9413414].
64 Olie JP, Gunn KP, Katz E. A double-blind placebo-controlled multicentre study of sertraline in the acute and continuation treatment of major depression. Eur Psychiat. 1997;12(1):34-41.
65 Hypericum Depression Trial Study Group. Effect of Hypericum perforatum (St John's wort) in major depressive disorder: a randomized controlled trial. JAMA. Apr. 10. 2002;287(14):1807-14. [pmid: 11939866].
66 Schneider LS, Nelson JC, Clary CM, et al. An 8-week multicenter, parallel-group, double-blind, placebo-controlled study of sertraline in elderly outpatients with major depression. Am J Psychiatry. Jul. 2003;160(7):1277-85. [pmid: 12832242].
67 Blumenthal JA, Babyak MA, Doraiswamy PM, et al. Exercise and pharmacotherapy in the treatment of major depressive disorder. Psychosom Med. 2007:587-96. [pmid: 17846259].
68 Munizza C, Olivieri L, Di Loreto G, et al. A comparative, randomized, double-blind study of trazodone prolonged-release and sertraline in the treatment of major depressive disorder. Curr Med Res Opin. 2006:1703-13. [pmid: 16968574].
69 Mehtonen OP, Sogaard J, Roponen P, et al. Randomized, double-blind comparison of venlafaxine and sertraline in outpatients with major depressive disorder. Venlafaxine 631 Study Group. J Clin Psychiatry. Feb. 2000;61(2):95-100. [pmid: 10732656].
70 Sir A, D'Souza RF, Uguz S, et al. Randomized trial of sertraline versus venlafaxine XR in major depression: efficacy and discontinuation symptoms. J Clin Psychiatry. Oct. 2005;66(10):1312-20. [pmid: 16259546].
71 Shelton RC, Haman KL, Rapaport MH, et al. A randomized, double-blind, active-control study of sertraline versus venlafaxine XR in major depressive disorder. J Clin Psychiatry. 2006:1674-81. [pmid: 17196045].
72 Thase ME. Efficacy and tolerability of once-daily venlafaxine extended release (XR) in outpatients with major depression. The Venlafaxine XR 209 Study Group. J Clin Psychiatry. Sep. 1997;58(9):393-8. [pmid: 9378690].
73 Perry PJ, Garvey MJ, Kelly MW, et al. A comparative trial of fluoxetine versus trazodone in outpatients with major depression. J Clin Psychiatry. Aug. 1989;50(8):290-4. [pmid: 2668259].
74 Beasley CM Jr., Dornseif BE, Pultz JA, et al. Fluoxetine versus trazodone: efficacy and activating-sedating effects. J Clin Psychiatry. Jul. 1991;52(7):294-9. [pmid: 2071559].
75 Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry. Apr. 1997;58(4):146-52. [pmid: 9164424].
76 Ushiroyama T, Ikeda A, Ueki M. Evaluation of double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients in menopause transition. J Med. 2004:151-62. [pmid: 18084873].
77 Nemeroff CB, Ninan PT, Ballenger J, et al. Double-blind multicenter comparison of fluvoxamine versus sertraline in the treatment of depressed outpatients. Depression. 1995;3(4):163-9.
78 Schatzberg AF, Kremer C, Rodrigues HE, et al. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):541-50. [pmid: 12213688].
79 Ehde DM, Kraft GH, Chwastiak L, et al. Efficacy of paroxetine in treating major depressive disorder in persons with multiple sclerosis. Gen Hosp Psychiatry. 2008:40-8. [pmid: 18164939].
80 McPartlin GM, Reynolds A, Anderson C, et al. A comparison of once-daily venlafaxine XR and paroxetine in depressed outpatients treated in general practice. Primary Care Psychiatry. 1998. 1998;4(3):127-32.
81 Ballus C, Quiros G, De Flores T, et al. The efficacy and tolerability of venlafaxine and paroxetine in outpatients with depressive disorder or dysthymia. Int Clin Psychopharmacol. Jan. 2000;15(1):43-8. [pmid: 10836286].
82 Kremer JM, Westhovens R, Leon M, et al. Treatment of rheumatoid arthritis by selective inhibition of T-cell activation with fusion protein CTLA4Ig. N Engl J Med. Nov. 13. 2003;349(20):1907-15. [pmid: 14614165].
83 Kremer JM, Genant HK, Moreland LW, et al. Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis: a randomized trial. Ann Intern Med. Jun. 20. 2006;144(12):865-76. [pmid: 16785475].
84 Schiff M, Keiserman M, Codding C, et al. Efficacy and safety of abatacept or infliximab vs placebo in ATTEST: a phase III, multi-centre, randomised, double-blind, placebo-controlled study in patients with rheumatoid arthritis and an inadequate response to methotrexate. Ann Rheum Dis. Aug. 2008;67(8):1096-103. [pmid: 18055472].
85 Furst DE, Schiff MH, Fleischmann RM, et al. Adalimumab, a fully human anti tumor necrosis factor-alpha monoclonal antibody, and concomitant standard antirheumatic therapy for the treatment of rheumatoid arthritis: results of STAR (Safety Trial of Adalimumab in Rheumatoid Arthritis). J Rheumatol. Dec. 2003;30(12):2563-71. [pmid: 14719195].
86 van de Putte LB, Rau R, Breedveld FC, et al. Efficacy and safety of the fully human anti-tumour necrosis factor alpha monoclonal antibody adalimumab (D2E7) in DMARD refractory patients with rheumatoid arthritis: a 12 week, phase II study. Ann Rheum Dis. Dec. 2003;62(12):1168-77. [pmid: 14644854].
87 Weinblatt ME, Keystone EC, Furst DE, et al. Adalimumab, a fully human anti-tumor necrosis factor alpha monoclonal antibody, for the treatment of rheumatoid arthritis in patients taking concomitant methotrexate: the ARMADA trial. Arthritis Rheum. Jan. 2003;48(1):35-45. [pmid: 12528101].
88 Keystone EC, Kavanaugh AF, Sharp JT, et al. Radiographic, clinical, and functional outcomes of treatment with adalimumab (a human anti-tumor necrosis factor monoclonal antibody) in patients with active rheumatoid arthritis receiving concomitant methotrexate therapy: a randomized, placebo-controlled, 52-week trial. Arthritis Rheum. May. 2004;50(5):1400-11. [pmid: 15146409].
89 van de Putte LB, Atkins C, Malaise M, et al. Efficacy and safety of adalimumab as monotherapy in patients with rheumatoid arthritis for whom previous disease modifying antirheumatic drug treatment has failed. Ann Rheum Dis. May. 2004;63(5):508-16. [pmid: 15082480].
90 Kim HY, Lee SK, Song YW, et al. A randomized, double-blind, placebo-controlled, phase III study of the human anti-tumor necrosis factor antibody adalimumab administered as subcutaneous injections in Korean rheumatoid arthritis patients treated with methotrexate. APLAR J Rheumatol. 2007;10(1):9-16.
91 Chen DY, Chou SJ, Hsieh TY, et al. Randomized, double-blind, placebo-controlled, comparative study of human anti-TNF antibody adalimumab in combination with methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis. J Formos Med Assoc. Apr. 2009;108(4):310-9. [pmid: 19369178].
92 Bresnihan B, Alvaro-Gracia JM, Cobby M, et al. Treatment of rheumatoid arthritis with recombinant human interleukin-1 receptor antagonist. Arthritis Rheum. Dec. 1998;41(12):2196-204. [pmid: 9870876].
93 Cohen S, Hurd E, Cush J, et al. Treatment of rheumatoid arthritis with anakinra, a recombinant human interleukin-1 receptor antagonist, in combination with methotrexate: results of a twenty-four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Mar. 2002;46(3):614-24. [pmid: 11920396].
94 Cohen SB, Moreland LW, Cush JJ, et al. A multicentre, double blind, randomised, placebo controlled trial of anakinra (Kineret), a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis treated with background methotrexate. Ann Rheum Dis. Sep. 2004;63(9):1062-8. [pmid: 15082469].
95 Moreland LW, Baumgartner SW, Schiff MH, et al. Treatment of rheumatoid arthritis with a recombinant human tumor necrosis factor receptor (p75)-Fc fusion protein. N Engl J Med. Jul. 17. 1997;337(3):141-7. [pmid: 9219699].
96 Moreland LW, Schiff MH, Baumgartner SW, et al. Etanercept therapy in rheumatoid arthritis. A randomized, controlled trial. Ann Intern Med. Mar. 16. 1999;130(6):478-86. [pmid: 10075615].
97 Weinblatt ME, Kremer JM, Bankhurst AD, et al. A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. N Engl J Med. Jan. 28. 1999;340(4):253-9. [pmid: 9920948].
98 Lan JL, Chou SJ, Chen DY, et al. A comparative study of etanercept plus methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis: a 12-week, double-blind, randomized, placebo-controlled study. J Formos Med Assoc. Aug. 2004;103(8):618-23. [pmid: 15340661].
99 Kay J, Matteson EL, Dasgupta B, et al. Golimumab in patients with active rheumatoid arthritis despite treatment with methotrexate: a randomized, double-blind, placebo-controlled, dose-ranging study. Arthritis Rheum. Apr. 2008;58(4):964-75. [pmid: 18383539].
100 Keystone EC, Genovese MC, Klareskog L, et al. Golimumab, a human antibody to tumour necrosis factor {alpha} given by monthly subcutaneous injections, in active rheumatoid arthritis despite methotrexate therapy: the GO-FORWARD Study. Ann Rheum Dis. Jun. 2009;68(6):789-96. [pmid: 19066176].
101 Maini R, St Clair EW, Breedveld F, et al. Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a randomised phase III trial. ATTRACT Study Group. Lancet. Dec. 4. 1999;354(9194):1932-9. [pmid: 10622295].
102 Kavanaugh A, St Clair EW, McCune WJ, et al. Chimeric anti-tumor necrosis factor-alpha monoclonal antibody treatment of patients with rheumatoid arthritis receiving methotrexate therapy. J Rheumatol. Apr. 2000;27(4):841-50. [pmid: 10782805].
103 Abe T, Takeuchi T, Miyasaka N, et al. A multicenter, double-blind, randomized, placebo controlled trial of infliximab combined with low dose methotrexate in Japanese patients with rheumatoid arthritis. J Rheumatol. Jan. 2006;33(1):37-44. [pmid: 16395748].
104 Westhovens R, Yocum D, Han J, et al. The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum. Apr. 2006;54(4):1075-86. [pmid: 16572442].
105 Zhang FC, Hou Y, Huang F, et al. Infliximab versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a preliminary study from China. APLAR J Rheumatol. 2006;9(2):127-30.
106 Edwards JC, Szczepanski L, Szechinski J, et al. Efficacy of B-cell-targeted therapy with rituximab in patients with rheumatoid arthritis. N Engl J Med. Jun. 17. 2004;350(25):2572-81. [pmid: 15201414].
107 Emery P, Deodhar A, Rigby WF, et al. Efficacy and safety of different doses and retreatment of rituximab: a randomised, placebo-controlled trial in patients who are biological naive with active rheumatoid arthritis and an inadequate response to methotrexate (Study Evaluating Rituximab's Efficacy in MTX iNadequate rEsponders (SERENE)). Ann Rheum Dis. Sep. 2010;69(9):1629-35. [pmid: 20488885].
108 Maini RN, Taylor PC, Szechinski J, et al. Double-blind randomized controlled clinical trial of the interleukin-6 receptor antagonist, tocilizumab, in European patients with rheumatoid arthritis who had an incomplete response to methotrexate. Arthritis Rheum. Sep. 2006;54(9):2817-29. [pmid: 16947782].
109 Genovese MC, McKay JD, Nasonov EL, et al. Interleukin-6 receptor inhibition with tocilizumab reduces disease activity in rheumatoid arthritis with inadequate response to disease-modifying antirheumatic drugs: the tocilizumab in combination with traditional disease-modifying antirheumatic drug therapy study. Arthritis Rheum. Oct. 2008;58(10):2968-80. [pmid: 18821691].
110 Smolen JS, Beaulieu A, Rubbert-Roth A, et al. Effect of interleukin-6 receptor inhibition with tocilizumab in patients with rheumatoid arthritis (OPTION study): a double-blind, placebo-controlled, randomised trial. Lancet. Mar. 22. 2008;371(9617):987-97. [pmid: 18358926].
111 Kremer JM, Blanco R, Brzosko M, et al. Tocilizumab inhibits structural joint damage in rheumatoid arthritis patients with inadequate responses to methotrexate: results from the double-blind treatment phase of a randomized placebo-controlled trial of tocilizumab safety and prevention of structural joint damage at one year. Arthritis Rheum. Mar. 2011;63(3):609-21. [pmid: 21360490].