# WinBUGS Code Used in Bayesian Mixed Treatment Comparisons Meta-Analysis

The WinBUGS code used to conduct Bayesian MTC meta-analyses is given below. WinBUGS Version 1.4.3 was used for all analyses. The code was adapted from code developed for the NICE Evidence Synthesis Technical Series Documents 2 and 3.^1, 2^

## KQ1 Random Effects Model for Dichotomous Data

# Binomial likelihood, logit link
# Random effects model for multi-arm trials

model{                   # *** PROGRAM STARTS

for(i in 1:ns){          # LOOP THROUGH STUDIES
   w[i,1] <- 0  # adjustment for multi-arm trials is zero for control arm
   delta[i,1] <- 0      # treatment effect is zero for control arm
   mu[i] ∼ dnorm(0,.0001)       # vague priors for all trial baselines
   for (k in 1:na[i]) {     # LOOP THROUGH ARMS
      r[i,k] ∼ dbin(p[i,k],n[i,k]) # binomial likelihood
      logit(p[i,k]) <- mu[i] + delta[i,k] # model for linear predictor
      rhat[i,k] <- p[i,k] * n[i,k] # expected value of the numerators

#Deviance contribution
    dev[i,k] <- 2 * (r[i,k] * (log(r[i,k])-log(rhat[i,k]))
      + (n[i,k]-r[i,k]) * (log(n[i,k]-r[i,k]) - log(n[i,k]-rhat[i,k]))) }

# summed residual deviance contribution for this trial
  resdev[i] <- sum(dev[i,1:na[i]])
  for (k in 2:na[i]) {     # LOOP THROUGH ARMS
# trial-specific LOR distributions
      delta[i,k] ∼ dnorm(md[i,k],taud[i,k])
# mean of LOR distributions (with multi-arm trial correction)
      md[i,k] <- d[t[i,k]] - d[t[i,1]] + sw[i,k]
# precision of LOR distributions (with multi-arm trial correction)
      taud[i,k] <- tau *2*(k-1)/k
# adjustment for multi-arm RCTs
      w[i,k] <- (delta[i,k] - d[t[i,k]] + d[t[i,1]])
# cumulative adjustment for multi-arm trials
      sw[i,k] <- sum(w[i,1:k-1])/(k-1)
   }
 }
totresdev <- sum(resdev[])     # Total Residual Deviance
d[1]<-0    # treatment effect is zero for reference treatment
# vague priors for treatment effects
for (k in 2:nt){ d[k] ∼ dnorm(0,.0001) }
sd ∼ dunif(0,5) # vague prior for between-trial SD
tau <- pow(sd,-2) # between-trial precision = (1/between-trial variance)

# pairwise ORs and LORs for all possible pair-wise comparisons, if nt>2
for (c in 1:(nt-1)) {
for (k in (c+1):nt) {
or[c,k] <- exp(d[k] - d[c])
lor[c,k] <- (d[k]-d[c])
}
}
# ranking on relative scale
for (k in 1:nt) {
rk[k] <- nt+1-rank(d[],k) # assumes events are “good”
# rk[k] <- rank(d[],k) # assumes events are “bad”
best[k] <- equals(rk[k],1) #calculate probability that treat k is best
}
}
# *** PROGRAM ENDS

### KQ 1 WinBUGS Dataset for SGA Dichotomous

#Full Network (star, closed loop, loop plus one, and ladder are subsets)
#Description of data inputs
       #ns = Number of studies
       #nt = Number of treatments (including placebo)
       #t[,x] = Treatment indicator
       #r[,x] = Number achieving response on HAM-D (50% improvement of scores from baseline)
       #n[,x]= Number of all randomized patients (ITT)
       #na[] = Number of arms in study


list(ns=64, nt=14)

t[,1]  t[,2]  t[,3]  r[,1]  r[,2]  r[,3]  n[,1]  n[,2]  n[,3]  na[]
1       2      7      73     76     83     152    150    154   3
1       2      12     66     78     66     124    122    118   3
1       2      12     55     77     79     121    120    119   3
1       4      NA     40     205    NA     161    324    NA    2
1       4      NA     39     52     NA     122    125    NA    2
1       4      NA     48     142    NA     126    249    NA    2
1       4      NA     36     46     NA     121    123    NA    2
1       4      5      61     132    74     164    315    159   3
1       5      NA     54     55     NA     141    141    NA    2
1       5      NA     49     64     NA     139    128    NA    2
1       5      NA     26     54     NA     122    123    NA    2
1       5      6      44     117    112    137    273    274   3
1       5      7      24     32     15     70     70     33    3
1       5      11     51     129    59     99     196    97    3
1       5      11     41     126    63     93     188    86    3
1       7      NA     18     132    NA     78     285    NA    2
1       7      11     10     31     32     19     54     55    3
1       7      14     37     45     51     102    104    102   3
1       7      14     41     52     54     98     103    100   3
1       8      NA     5      9      NA     18     18     NA    2
1       10     NA     15     25     NA     42     39     NA    2
1       10     NA     14     41     NA     45     90     NA    2
1       11     NA     12     24     NA     56     55     NA    2
1       12     NA     45     70     NA     129    129    NA    2
1       12     NA     16     19     NA     49     49     NA    2
1       12     NA     49     77     NA     150    149    NA    2
1       12     NA     43     65     NA     129    132    NA    2
1       12     NA     13     26     NA     116    111    NA    2
1       14     NA     29     53     NA     102    95     NA    2
2       7      NA     37     35     NA     61     62     NA    2
2       12     NA     81     93     NA     122    126    NA    2
2       13     NA     33     21     NA     63     61     NA    2
3       6      NA     87     83     NA     120    120    NA    2
3       8      NA     33     31     NA     108    109    NA    2
5       6      NA     66     83     NA     138    140    NA    2
5       6      NA     81     94     NA     151    144    NA    2
5       11     NA     144    157    NA     238    240    NA    2
6       7      NA     94     89     NA     123    117    NA    2
6       11     NA     175    146    NA     232    227    NA    2
6       12     NA     75     74     NA     107    108    NA    2
6       14     NA     59     47     NA     98     100    NA    2
7       9      NA     30     35     NA     66     66     NA    2
7       10     NA     27     29     NA     61     64     NA    2
7       11     NA     67     67     NA     101    102    NA    2
7       11     NA     27     30     NA     45     45     NA    2
7       11     NA     26     25     NA     50     50     NA    2
7       11     12     57     64     70     92     96     96    3
7       12     NA     35     48     NA     120    118    NA    2
7       12     NA     63     73     NA     144    142    NA    2
7       14     NA     31     36     NA     54     55     NA    2
7       14     NA     35     35     NA     47     40     NA    2
7       14     NA     98     81     NA     170    171    NA    2
7       14     NA     153    170    NA     186    196    NA    2
7       14     NA     95     107    NA     161    153    NA    2
7       14     NA     34     48     NA     73     73     NA    2
9       11     NA     74     66     NA     139    136    NA    2
9       13     NA     61     51     NA     100    100    NA    2
10      11     NA     11     16     NA     20     20     NA    2
10      12     NA     42     41     NA     78     82     NA    2
11      13     NA     48     48     NA     53     55     NA    2
12      13     NA     37     46     NA     60     62     NA    2
12      14     NA     41     49     NA     72     75     NA    2
12      14     NA     56     56     NA     79     84     NA    2
12      14     NA     45     49     NA     82     78     NA    2
END

#Set Initial Values
#chain 1
list(d=c( NA, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0), sd=1,
mu=c(0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0))
#chain 2
list(d=c( NA, -1, -1, -1, -1, -1, -1, -1, -1, -1, -1, -1, -1, -1), sd=4,
mu=c(-3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
     -3, -3, -3, -3))
#chain 3
list(d=c( NA, 2, 2, 2, 2, 2, 2, 2, 2, 2, 2, 2, 2, 2), sd=2,
mu=c(-3, 5, -1, -3, 7, -3, -4, -3, -3, 0,
     -3, -3, 0, 3, 5, -3, -3, -1, -3, -7,
     -3, -3, 5, -1, 7, 0, 1,-4, 5, 0,
     -3, 5, -1, -3, 7, -3, -4, -3, -3, 0,
     -3, -3, 0, 3, 5, -3, -3, -1, -3, -7,
     -3, -3, 5, -1, 7, 0, 1,-4, 5, 0,
     1, -1, 5, -4))

### KQ1 WinBUGS Dataset for RA Dichotomous

#Full Network (star, closed loop, loop plus one, and ladder are subsets)
#Description of data inputs
       #ns = Number of studies
       #nt = Number of treatments (including placebo)
       #t[,x] = Treatment indicator
       #r[,x] = Number achieving response on ACR50
       #n[,x]= Number of all randomized patients (ITT)
       #na[] = Number of arms in study


list(ns=31, nt=9)

t[,1] t[,2] t[,3] r[,1] r[,2] r[,3] n[,1] n[,2] n[,3] na[]
1      2     NA    36    169   NA    219   433   NA   2
1      2     NA    14    42    NA    119   115   NA   2
1      2     7     22    63    61    110   156   165  3
1      3     NA    9     84    NA    110   328   NA   2
1      3     NA    1     36    NA    70    142   NA   2
1      3     NA    5     37    NA    62    67    NA   2
1      3     NA    2     12    NA    12    35    NA   2
1      3     NA    36    92    NA    318   318   NA   2
1      3     NA    9     28    NA    63    65    NA   2
1      3     NA    19    166   NA    200   419   NA   2
1      4     NA    9     33    NA    121   232   NA   2
1      4     NA    2     22    NA    48    105   NA   2
1      4     NA    20    43    NA    253   253   NA   2
1      4     NA    0     16    NA    12    42    NA   2
1      5     NA    1     23    NA    30    59    NA   2
1      5     NA    3     25    NA    44    44    NA   2
1      5     NA    3     19    NA    29    29    NA   2
1      5     NA    4     31    NA    80    78    NA   2
1      6     NA    13    31    NA    133   89    NA   2
1      6     NA    2     13    NA    35    35    NA   2
1      7     NA    4     33    NA    47    100   NA   2
1      7     NA    33    229   NA    363   721   NA   2
1      7     NA    22    38    NA    86    87    NA   2
1      7     NA    1     3     NA    7     14    NA   2
1      7     NA    4     94    NA    88    340   NA   2
1      8     NA    5     17    NA    40    40    NA   2
1      8     NA    16    88    NA    172   340   NA   2
1      9     NA    14    45    NA    49    99    NA   2
1      9     NA    37    302   NA    415   805   NA   2
1      9     NA    22    157   NA    204   419   NA   2
1      9     NA    38    228   NA    394   802   NA   2
END

#Initial Values
#chain 1
list(d=c( NA, 0, 0, 0, 0, 0, 0, 0, 0), sd=1, mu=c(0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0))
#chain 2
list(d=c( NA, -1, -1, -1, -1, -1, -1, -1, -1), sd=4, mu=c(-3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -
3, -3, -3, -3, -3, -3, -3, -3, -3 , -3, -3, -3 , -3, -3, -3 , -3, -3, -3))
#chain 3
list(d=c( NA, 2, 2, 2, 2, 2, 2, 2, 2), sd=2, mu=c(-3, 5, -1, -3, 7, -3, -4, -3, -3, 0, -3, -3,0, 3, 5, -3, -3,
-1, -3, -7, -3, -3, 5, -1,7, 0, 1,-4, 5, 0, -1))

## KQ1 Random Effects Model for Continuous Data

# Normal likelihood, identity link
# Random effects model for multi-arm trials

model{                  # *** PROGRAM STARTS

for(i in 1:ns){         # LOOP THROUGH STUDIES
   w[i,1] <- 0 # adjustment for multi-arm trials is zero for control arm
   delta[i,1] <- 0     # treatment effect is zero for control arm
   mu[i] ∼ dnorm(0,.0001)      # vague priors for all trial baselines
   for (k in 1:na[i]) {    # LOOP THROUGH ARMS
       var[i,k] <- pow(se[i,k],2)   # calculate variances
       prec[i,k] <- 1/var[i,k]     # set precisions
       y[i,k] ∼ dnorm(theta[i,k],prec[i,k]) # binomial likelihood
       theta[i,k] <- mu[i] + delta[i,k] # model for linear predictor
#Deviance contribution
       dev[i,k] <- (y[i,k]-theta[i,k])*(y[i,k]-theta[i,k])*prec[i,k]
   }
# summed residual deviance contribution for this trial
  resdev[i] <- sum(dev[i,1:na[i]])
  for (k in 2:na[i]) {      # LOOP THROUGH ARMS
# trial-specific LOR distributions
       delta[i,k] ∼ dnorm(md[i,k],taud[i,k])
# mean of LOR distributions, with multi-arm trial correction
       md[i,k] <- d[t[i,k]] - d[t[i,1]] + sw[i,k]
# precision of LOR distributions (with multi-arm trial correction)
       taud[i,k] <- tau *2*(k-1)/k
# adjustment, multi-arm RCTs
       w[i,k] <- (delta[i,k] - d[t[i,k]] + d[t[i,1]])
# cumulative adjustment for multi-arm trials
       sw[i,k] <- sum(w[i,1:k-1])/(k-1)
   }
 }
totresdev <- sum(resdev[])        #Total Residual Deviance
d[1]<-0    # treatment effect is zero for control arm
# vague priors for treatment effects
for (k in 2:nt){ d[k] ∼ dnorm(0,.0001) }
sd ∼ dunif(0,5) # vague prior for between-trial SD
tau <- pow(sd,-2) # between-trial precision = (1/between-trial variance)

# All pairwise comparisons
for (c in 1:(nt-1)) { for (k in (c+1):nt) { diff[c,k] <- (d[c] - d[k] )}}
for (k in 1:nt) {
rk[k] <- nt+1-rank(d[],k) # assumes events are “good”
#rk[k] <- rank(d[],k) # assumes events are “bad”
best[k] <- equals(rk[k],1) #calculate probability that treat k is best
}
}                          # *** PROGRAM ENDS

### KQ 1 WinBUGS Dataset for SGA Continuous

#Full Network (star, closed loop, loop plus one, and ladder are subsets)
#Description of data inputs
       #ns = Number of studies
       #nt = Number of treatments (including placebo)
       #t[,x] = Treatment indicator
       #y[,x] = Mean change from baseline in HAM-D score
       #se[,x]= Standard error of mean change from baseline in HAM-D score
       #na[] = Number of arms in study
list(ns=40, nt=14)

t[,1]   t[,2]   t[,3]   y[,1]   y[,2]   y[,3]   se[,1]   se[,2]   se[,3]   na[]
1        4       NA      -10.7   -13.2   NA      0.84     0.82     NA      2
1        4       NA      -9.3    -12.6   NA      0.74     0.75     NA      2
1        4       NA      -7.5    -9.1    NA      0.66     0.67     NA      2
1        5       6       -5.97   -7.61   -7.22   0.58     0.42     0.4     3
1        5       11      -8.8    -12.1   -11.7   0.5      0.5      0.5     3
1        5       11      -10.8   -12.1   -11.9   0.5      0.5      0.5     3
1        5       NA      -10.27          -10.85           NA       0.67    0.69    NA      2
1        7       11      -11.6   -10.8   -11.1   2.04     1.29     1.27    3
1        7       NA      -7.9    -10.3   NA      0.44     0.49     NA      2
1        7       NA      -7      -11.2   NA      0.98     0.86     NA      2
1        11      NA      -7.6    -7.8    NA      1.2      1.13     NA      2
1        12      NA      -8.8    -11.1   NA      0.65     0.63     NA      2
1        12      NA      -6.1    -6.1    NA      1.04     0.96     NA      2
1        12      NA      -9.2    -10.53          NA       0.67     0.72    NA      2
1        12      NA      -8.16   -11.66          NA       0.66     0.69    NA      2
1        14      NA      -7.3    -11.7   NA      0.71     0.75     NA      2
2        12      NA      -15.5   -16.3   NA      0.66     0.69     NA      2
3        6       NA      -13.8   -14.7   NA      0.69     0.76     NA      2
6        5       NA      -11.1   -9.6    NA      0.59     0.68     NA      2
6        7       NA      -15.8   -14.7   NA      0.59     0.74     NA      2
6        12      NA      -16.9   -16.1   NA      0.7      0.8      NA      2
6        14      NA      -14.9   -12.9   NA      0.91     0.92     NA      2
7        10      NA      -12.2   -11.4   NA      0.79     0.83     NA      2
7        11      NA      -14.78          -13.92           NA       0.11    0.11     NA      2
7        11      NA      -15     -17.3   NA      1.61     1.56     NA      2
7        13      NA      -12.2   -13.9   NA      0.91     1.02     NA      2
7        13      NA      -14.8   -17.1   NA      1.74     1.02     NA      2
7        14      NA      -14.4   -16.1   NA      0.88     0.7      NA      2
7        14      NA      -10.4   -14.4   NA      1.05     0.95     NA      2
8        11      NA      -15.9   -13.9   NA      0.66     0.66     NA      2
8        11      NA      -13.45          -12.86           NA       1.25    1.27     NA      2
8        12      NA      -23.7   -18     NA      1.72     1.5      NA      2
8        12      NA      -10.61          -10.98           NA       1.11    0.9      NA      2
9        11      NA      -9.22   -7.29   NA      0.51     0.54     NA      2
11       13      NA      -15     -14.6   NA      0.68     0.66     NA      2
11       14      NA      -14.1   -14.7   NA      0.6      0.57     NA      2
11       14      NA      -15.5   -15.7   NA      0.95     0.9      NA      2
12       13      NA      -11.5   -12.9   NA      1.08     1.15     NA      2
12       14      NA      -11.3   -12.7   NA      0.61     0.64     NA      2
12       14      NA      -15.9   -14.3   NA      0.95     0.94     NA      2
END

#Initial Values
#chain 1
list(d=c( NA, 0,0,0,0,0,0,0,0,0,0,0,0,0), sd=1, mu=c(0, 0, 0, 0, 0, 0, 0, 0 , 0, 0,
0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
0, 0, 0, 0, 0, 0, 0, 0, 0, 0))
#chain 2
list(d=c( NA, -1,-3,-1,1,3,-1,-3, -1,1,3,-1,-3, 1), sd=4, mu=c(-3, -3, -3, -3, -3, -3, -3,-3,-3,-3,
-3, -3, -3, -3, -3, -3,-3,-3,-3,-3,
-3, -3, -3, -3, -3, -3,-3,-3,-3,-3,
-3, -3, -3, -3, -3, -3,-3,-3,-3,-3))
#chain 3
list(d=c( NA, 2,2,2,2,2,2,2,2,2,2,2,2,2), sd=2, mu=c(-3, 5, -1, -3, 7, -3, -4, -3, 5, -1,
-3, 5, -1, -3, 7, -3, -4, -3, 5, -1,
-3, 5, -1, -3, 7, -3, -4, -3, 5, -1,
-3, 5, -1, -3, 7, -3, -4, -3, 5, -1))

## KQ2 Random Effects Meta-Regression Model With a Subgroup Indicator Covariate

# Binomial likelihood, logit link, subgroup
# Random effects model for multi-arm trials

model{                  # *** PROGRAM STARTS
for(i in 1:ns){         # LOOP THROUGH STUDIES
   w[i,1] <- 0 # adjustment for multi-arm trials is zero for control arm
   delta[i,1] <- 0      # treatment effect is zero for control arm
   mu[i] ∼ dnorm(0,.0001)       # vague priors for all trial baselines
   for (k in 1:na[i]) {     # LOOP THROUGH ARMS
      r[i,k] ∼ dbin(p[i,k],n[i,k]) # binomial likelihood
# model for linear predictor, covariate effect relative to treat in arm 1
      logit(p[i,k]) <- mu[i] + delta[i,k]
           + (beta[t[i,k]]-beta[t[i,1]]) * x[i]
      rhat[i,k] <- p[i,k] * n[i,k] # expected value of the numerators
#Deviance contribution
      dev[i,k] <- 2 * (r[i,k] * (log(r[i,k])-log(rhat[i,k]))
        + (n[i,k]-r[i,k]) * (log(n[i,k]-r[i,k]) - log(n[i,k]-rhat[i,k]))) }
# summed residual deviance contribution for this trial
  resdev[i] <- sum(dev[i,1:na[i]])
  for (k in 2:na[i]) {      # LOOP THROUGH ARMS
# trial-specific LOR distributions
      delta[i,k] ∼ dnorm(md[i,k],taud[i,k])
# mean of LOR distributions (with multi-arm trial correction)
      md[i,k] <- d[t[i,k]] - d[t[i,1]] + sw[i,k]
# precision of LOR distributions (with multi-arm trial correction)
      taud[i,k] <- tau *2*(k-1)/k
# adjustment for multi-arm RCTs
      w[i,k] <- (delta[i,k] - d[t[i,k]] + d[t[i,1]])
# cumulative adjustment for multi-arm trials
      sw[i,k] <- sum(w[i,1:k-1])/(k-1)
   }
 }
totresdev <- sum(resdev[])         # Total Residual Deviance
d[1]<-0    # treatment effect is zero for reference treatment
beta[1] <- 0 # covariate effect is zero for reference treatment
for (k in 2:nt){ # LOOP THROUGH TREATMENTS
   d[k] ∼ dnorm(0,.0001) # vague priors for treatment effects
   beta[k] <- B # common covariate effect
 }
B ∼ dnorm(0,.0001) # vague prior for covariate effect
sd ∼ dunif(0,5) # vague prior for between-trial SD
tau <- pow(sd,-2) # between-trial precision = (1/between-trial variance)
# treatment effect when covariate = z[j]
for (k in 1:nt){ # LOOP THROUGH TREATMENTS
   for (j in 1:nz) { dz[j,k] <- d[k] + (beta[k]-beta[1])*z[j] }
 }
# pairwise ORs and LORs for all possible pair-wise comparisons, if nt>2
for (c in 1:(nt-1)) {
   for (k in (c+1):nt) {
# when covariate is zero
    or[c,k] <- exp(d[k] - d[c])
    lor[c,k] <- (d[k]-d[c])
# at covariate=z[j]
    for (j in 1:nz) {
       orz[j,c,k] <- exp(dz[j,k] - dz[j,c])
       lorz[j,c,k] <- (dz[j,k]-dz[j,c])
     }
   }
 }
}                           # *** PROGRAM ENDS

### KQ 2 WinBUGS Dataset for Meta-Regression With a Subgroup Indicator Covariate

# ns= number of studies; nt=number of treatments;
# z=values of covariate at which to calculate treatment effects; nz=length of z
list(ns=72, nt=14, z=c(1), nz=1)

t[,1]  t[,2]  t[,3]  r[,1]  r[,2]  r[,3]  n[,1]  n[,2]  n[,3]  x[]   na[]
1       2      7      73     76     83     152    150    154    0 3
1       2      12     66     78     66     124    122    118    0 3
1       2      12     55     77     79     121    120    119    0 3
1       3      NA     34     34     NA     90     84     NA     1 2
1       4      NA     40     205    NA     161    324    NA     0 2
1       4      NA     39     52     NA     122    125    NA     0 2
1       4      NA     48     142    NA     126    249    NA     0 2
1       4      NA     36     46     NA     121    123    NA     0 2
1       4      5      61     132    74     164    315    159    0 3
1       5      NA     54     55     NA     141    141    NA     0 2
1       5      NA     49     64     NA     139    128    NA     0 2
1       5      NA     26     54     NA     122    123    NA     0 2
1       5      6      44     117    112    137    273    274    0 3
1       5      7      24     32     15     70     70     33     0 3
1       5      11     51     129    59     99     196    97     0 3
1       5      11     41     126    63     93     188    86     0 3
1       7      NA     92     125    NA     336    335    NA     1 2
1       7      NA     18     132    NA     78     285    NA     0 2
1       7      11     10     31     32     19     54     55     0 3
1       7      14     37     45     51     102    104    102    0 3
1       7      14     41     52     54     98     103    100    0 3
1       8      NA     5      9      NA     18     18     NA     0 2
1       9      13     25     20     17     50     50     50     1 3
1       10     NA     15     25     NA     42     39     NA     0 2
1       10     NA     14     41     NA     45     90     NA     0 2
1       11     NA     12     24     NA     56     55     NA     0 2
1       11     11     72     85     100    180    168    177    1 3
1       12     NA     45     70     NA     129    129    NA     0 2
1       12     NA     16     19     NA     49     49     NA     0 2
1       12     NA     49     77     NA     150    149    NA     0 2
1       12     NA     43     65     NA     129    132    NA     0 2
1       12     NA     96     126    NA     376    371    NA     1 2
1       12     NA     13     26     NA     116    111    NA     0 2
1       14     NA     29     53     NA     102    95     NA     0 2
2       7      NA     37     35     NA     61     62     NA     0 2
2       11     NA     34     40     NA     48     52     NA     1 2
2       12     NA     81     93     NA     122    126    NA     0 2
2       13     NA     33     21     NA     63     61     NA     0 2
3       6      NA     87     83     NA     120    120    NA     0 2
3       8      NA     33     31     NA     108    109    NA     0 2
5       6      NA     66     83     NA     138    140    NA     0 2
5       6      NA     81     94     NA     151    144    NA     0 2
5       11     NA     144    157    NA     238    240    NA     0 2
6       7      NA     94     89     NA     123    117    NA     0 2
6       11     NA     175    146    NA     232    227    NA     0 2
6       12     NA     75     74     NA     107    108    NA     0 2
6       14     NA     59     47     NA     98     100    NA     0 2
7       9      NA     30     35     NA     66     66     NA     0 2
7       10     NA     27     29     NA     61     64     NA     0 2
7       11     NA     67     67     NA     101    102    NA     0 2
7       11     NA     27     30     NA     45     45     NA     0 2
7       11     NA     26     25     NA     50     50     NA     0 2
7       11     12     57     64     70     92     96     96     0 3
7       12     NA     84     85     NA     119    117    NA     1 2
7       12     NA     35     48     NA     120    118    NA     0 2
7       12     NA     63     73     NA     144    142    NA     0 2
7       14     NA     31     36     NA     54     55     NA     0 2
7       14     NA     35     35     NA     47     40     NA     0 2
7       14     NA     98     81     NA     170    171    NA     0 2
7       14     NA     153    170    NA     186    196    NA     0 2
7       14     NA     95     107    NA     161    153    NA     0 2
7       14     NA     34     48     NA     73     73     NA     0 2
8       12     NA     28     25     NA     40     48     NA     1 2
9       11     NA     74     66     NA     139    136    NA     0 2
9       13     NA     61     51     NA     100    100    NA     0 2
10      11     NA     11     16     NA     20     20     NA     0 2
10      12     NA     42     41     NA     78     82     NA     0 2
11      13     NA     48     48     NA     53     55     NA     0 2
12      13     NA     37     46     NA     60     62     NA     0 2
12      14     NA     41     49     NA     72     75     NA     0 2
12      14     NA     56     56     NA     79     84     NA     0 2
12      14     NA     45     49     NA     82     78     NA     0 2
END


#Initial Values
#chain 1
list(d=c( NA, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0), mu=c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0,
0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0,
0,0,0,0,0, 0,0,0,0,0, 0,0), B=0, sd=1)
#chain 2
list(d=c( NA, -1, -1, -2, -1, -1, -2, -1, -1, -2, -1, -1, -2, 1), mu=c(-3,-3, 3,-3, 3, -3, 3,-3, 3,-3,
-3,-3, 3, 3, -3, 3, -3, -3, 3, -3, 3,-3,3,-3, -3, 3,-3,3,-3, -3, 3,-3,3,-3,-3, 3,-3,3,-3, -3, 3,-3,3,-3,-3, 3,-3,3,-3, -3, 3,-3,3,-3,-3, 3,-3,3,-3,-3, 3,-3,3,-3,-3, 3,-3,3,-3, 3,-3 ), B=-1, sd=3)

## KQ2 Random Effects Continuous Covariate Meta-Regression Model

# Binomial likelihood, logit link
# Random effects model for multi-arm trials
model{                  # *** PROGRAM STARTS
for(i in 1:ns){         # LOOP THROUGH STUDIES
   w[i,1] <- 0 # adjustment for multi-arm trials is zero for control arm
   delta[i,1] <- 0      # treatment effect is zero for control arm
   mu[i] ∼ dnorm(0,.0001)       # vague priors for all trial baselines
   for (k in 1:na[i]) {    # LOOP THROUGH ARMS
      r[i,k] ∼ dbin(p[i,k],n[i,k]) # binomial likelihood
# model for linear predictor
      logit(p[i,k]) <- mu[i] + delta[i,k]
                + (beta[t[i,k]]-beta[t[i,1]]) * (x[i]-mx)
      rhat[i,k] <- p[i,k] * n[i,k] # expected value of the numerators
#Deviance contribution
      dev[i,k] <- 2 * (r[i,k] * (log(r[i,k])-log(rhat[i,k]))
        + (n[i,k]-r[i,k]) * (log(n[i,k]-r[i,k]) - log(n[i,k]-rhat[i,k]))) }
# summed residual deviance contribution for this trial
  resdev[i] <- sum(dev[i,1:na[i]])
  for (k in 2:na[i]) {     # LOOP THROUGH ARMS
# trial-specific LOR distributions
      delta[i,k] ∼ dnorm(md[i,k],taud[i,k])
# mean of LOR distributions (with multi-arm trial correction)
# covariate effect relative to treat in arm 1
      md[i,k] <- d[t[i,k]] - d[t[i,1]] + sw[i,k]
# precision of LOR distributions (with multi-arm trial correction)
      taud[i,k] <- tau *2*(k-1)/k
# adjustment for multi-arm RCTs
      w[i,k] <- (delta[i,k] - d[t[i,k]] + d[t[i,1]])
# cumulative adjustment for multi-arm trials
      sw[i,k] <- sum(w[i,1:k-1])/(k-1)
   }
 }
totresdev <- sum(resdev[])          # Total Residual Deviance
d[1]<-0 # treatment effect is zero for reference treatment
beta[1] <- 0 # covariate effect is zero for reference treatment
# vague priors for treatment effects
for (k in 2:nt){
   d[k] ∼ dnorm(0,.0001)
   beta[k] <- B # common covariate effect
 }
B ∼ dnorm(0,.0001) # vague prior for covariate effect
sd ∼ dunif(0,5) # vague prior for between-trial SD
tau <- pow(sd,-2) # between-trial precision = (1/between-trial variance)
# treatment effect when covariate = z[j] (un-centring treatment effects)
for (k in 1:nt){
   for (j in 1:nz) { dz[j,k] <- d[k] - (beta[k]-beta[1])*(mx-z[j]) }
 }
# pairwise ORs and LORs for all possible pair-wise comparisons, if nt>2
for (c in 1:(nt-1)) {
   for (k in (c+1):nt) {
# at mean value of covariate
     or[c,k] <- exp(d[k] - d[c])
     lor[c,k] <- (d[k]-d[c])
# at covariate=z[j]
     for (j in 1:nz) {
        orz[j,c,k] <- exp(dz[j,k] - dz[j,c])
        lorz[j,c,k] <- (dz[j,k]-dz[j,c])
      }
   }
}
# ranking on relative scale
for (k in 1:nt) {
rk[k] <- nt+1-rank(d[],k) # assumes events are “good”
#rk[k] <- rank(d[],k) # assumes events are “bad”
best[k] <- equals(rk[k],1) #calculate probability that treat k is best
}                            # *** PROGRAM ENDS

### KQ 2 WinBUGS Dataset for Continuous Covariate Meta-Regression

# Data (RA with ACR50 – covariate x[] is disease duration)
list(ns=28, nt=9, mx=8.50, z=c(1,2,10), nz=3)

t[,1]  t[,2]  t[,3]  na[]  n[,1]  n[,2]  n[,3]  r[,1]  r[,2]  r[,3]  x[]
1       2      NA    2     219    433    NA     36     169    NA     8.7
1       2      NA    2     119    115    NA     14     42     NA     9.3
1       2      7     3     110    156    165    22     63     61     7.87
1       3      NA    2     318    318    NA     36     92     NA     10.4
1       3      NA    2     70     142    NA     1      36     NA     10
1       3      NA    2     110    328    NA     9      84     NA     11.2
1       3      NA    2     200    419    NA     19     166    NA     10.9
1       3      NA    2     62     67     NA     5      37     NA     12.3
1       3      NA    2     63     65     NA     9      28     NA     6.85
1       3      NA    2     12     35     NA     2      12     NA     7.25
1       4      NA    2     121    232    NA     9      33     NA     3.9
1       4      NA    2     253    253    NA     20     43     NA     10.5
1       4      NA    2     48     105    NA     2      22     NA     7.55
1       5      NA    2     80     78     NA     4      31     NA     12
1       5      NA    2     30     59     NA     1      23     NA     13
1       6      NA    2     133    89     NA     13     31     NA     5.5
1       6      NA    2     35     35     NA     2      13     NA     7.8
1       7      NA    2     47     100    NA     4      33     NA     7.8
1       7      NA    2     7      14     NA     1      3      NA     6.2
1       7      NA    2     363    721    NA     33     229    NA     7.5
1       7      NA    2     86     87     NA     22     38     NA     7.55
1       7      NA    2     88     340    NA     4      94     NA     8.6
1       8      NA    2     172    340    NA     16     88     NA     7
1       8      NA    2     40     40     NA     5      17     NA     11.5
1       9      NA    2     204    419    NA     22     157    NA     7.65
1       9      NA    2     49     99     NA     14     45     NA     0.865
1       9      NA    2     415    805    NA     37     302    NA     9.8
1       9      NA    2     394    802    NA     38     228    NA     9
END


# Initial values for RE model
#chain 1
list(d=c( NA, 0,0,0,0,0,0, 0, 0), mu=c(0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
0, 0, 0, 0, 0), sd=1, B=0)
#chain 2
list(d=c( NA, -1,1,-1,1,-1,1, -1, 1), mu=c(-3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3,
-3, -3, -3, -3, -3, -3, -3, -3, -3, -3, -3 ), sd=0.5, B=-1)
#chain 3
list(d=c( NA, 2,-2,2,-2,2,-2, 2, -2), mu=c(-3, 5, -1, -3, 7, -3, -4, -3, -3, 0, 5, 0, -3, 5, -1, -3, 7, -3, -
4, -3, -3, 0, 5, 0, 1,-1, 3,4), sd=3, B=5)

### KQ 3 Simulation Code Related to Key Question 3

Initially, we created two master datasets generated from random binomial draws from which to sample sub-datasets for each of the different network pattern and sample size criteria. Each dataset reflected a different scenario we wanted to introduce to the Bayesian MTC models. The datasets were created from binomial distributions of varying probability of response and sample size. The SAS version 9.2 code is presented below.

/* master_even: dataset where drugs have equal efficacy and drug1 low efficacy */
data master_even (drop=i);
      do i=1 to 10000;
             r1 = rand(‘BINOM’,0.1, 100);
             r2 = rand(‘BINOM’,0.5, 100);
             r3 = rand(‘BINOM’,0.5, 100);
             r4 = rand(‘BINOM’,0.5, 100);
             output;
      end;
run;

/* master_winnner: dataset where one drug has a high efficacy and the others low efficacy */
data master_winner (drop=i);
n=100;
      do i=1 to 10000;
             r1 = rand(‘BINOM’,0.2, 100);
             r2 = rand(‘BINOM’,0.2, 100);
             r3 = rand(‘BINOM’,0.2, 100);
             r4 = rand(‘BINOM’,0.8, 100);
             output;
      end;
run;

## KQ 3 WinBUGS Datasets

From these master datasets, sub-datasets for WinBUGS were created for each of the network patterns and sample size criteria. A total of 40,000 datasets were created by taking successive studies in each of the master datasets. In this way, studies were sampled without replacement for each of the datasets. An example dataset is shown below.

We used macros created in SAS to invoke repeated calls of openBUGS for each model run (for a total of 40,000 model runs). OpenBUGS was utilized instead of winBUGS since the simulations were performed on UNC's linux cluster. The output, in this case, the ‘best’ statistic, was parsed and processed in SAS for post-data management and panel plot creation.

#Star network, study sample size = 2
#Description of data inputs
#ns = Number of studies
#nt = Number of treatments (including placebo)
#t[,x] = Treatment indicator
#r[,x] = Number achieving response
#n[,x]= Number of all randomized patients (ITT)
#na[] = Number of arms in study

list(ns=6, nt=4)

t[,1]  t[,2]  t[,3]  r[,1]  r[,2]  r[,3]  n[,1]  n[,2]  n[,3]  na[]
1       2      7      73     76     83     152    150    154    2
1       2      12     66     78     66     124    122    118    2
1       2      12     55     77     79     121    120    119    2
1       4      NA     40     205    NA     161    324    NA     2
1       4      NA     39     52     NA     122    125    NA     2
1       4      NA     48     142    NA     126    249    NA     2
END
#Set Initial Values
#chain 1
list(d=c( NA, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0, 0), sd=1,
mu=c(0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0, 0, 0, 0, 0, 0, 0,
     0, 0, 0, 0))

## Random Effects Model for Dichotomous Data

# Binomial likelihood, logit link
# Random effects model for multi-arm trials

model{                  # *** PROGRAM STARTS

for(i in 1:ns){         # LOOP THROUGH STUDIES
   w[i,1] <- 0 # adjustment for multi-arm trials is zero for control arm
   delta[i,1] <- 0      # treatment effect is zero for control arm
   mu[i] ∼ dnorm(0,.0001)       # vague priors for all trial baselines
   for (k in 1:na[i]) {      # LOOP THROUGH ARMS
      r[i,k] ∼ dbin(p[i,k],n[i,k]) # binomial likelihood
      logit(p[i,k]) <- mu[i] + delta[i,k] # model for linear predictor
      rhat[i,k] <- p[i,k] * n[i,k] # expected value of the numerators

#Deviance contribution
      dev[i,k] <- 2 * (r[i,k] * (log(r[i,k])-log(rhat[i,k]))
        + (n[i,k]-r[i,k]) * (log(n[i,k]-r[i,k]) - log(n[i,k]-rhat[i,k]))) }

# summed residual deviance contribution for this trial
  resdev[i] <- sum(dev[i,1:na[i]])
  for (k in 2:na[i]) {     # LOOP THROUGH ARMS
# trial-specific LOR distributions
      delta[i,k] ∼ dnorm(md[i,k],taud[i,k])
# mean of LOR distributions (with multi-arm trial correction)
      md[i,k] <- d[t[i,k]] - d[t[i,1]] + sw[i,k]
# precision of LOR distributions (with multi-arm trial correction)
      taud[i,k] <- tau *2*(k-1)/k
# adjustment for multi-arm RCTs
      w[i,k] <- (delta[i,k] - d[t[i,k]] + d[t[i,1]])
# cumulative adjustment for multi-arm trials
      sw[i,k] <- sum(w[i,1:k-1])/(k-1)
   }
 }
totresdev <- sum(resdev[])        # Total Residual Deviance
d[1]<-0 # treatment effect is zero for reference treatment
# vague priors for treatment effects
for (k in 2:nt){ d[k] ∼ dnorm(0,.0001) }
sd ∼ dunif(0,5) # vague prior for between-trial SD
tau <- pow(sd,-2) # between-trial precision = (1/between-trial variance)
# ranking on relative scale
for (k in 1:nt) {
rk[k] <- nt+1-rank(d[],k) # assumes events are “good”
# rk[k] <- rank(d[],k) # assumes events are “bad”
best[k] <- equals(rk[k],1) #calculate probability that treat k is best
}
}
# *** PROGRAM ENDS

## References

1 Dias S, Sutton AJ, Welton NJ, et al. NICE DSU Technical Support Document 3: Heterogeneity: subgroups, meta-regression, bias and bias-adjustment. Report by the Decision Support Unit. 2011. http://www.nicedsu.org.uk/TSD3%20Heterogeneity.final%20report.08.05.12.pdf. May 4, 2012.
2 Dias S, Welton NJ, Sutton AJ, et al. NICE DSU Technical Support Document 2: A Generalised Linear Modelling Framework for Pairwise and Network Meta-Analysis of Randomised Controlled Trials. Last updated August 2011. 2011. http://www.nicedsu.org.uk.