# References

1 Jansen JP, Fleurence R, Devine B, et al. Interpreting indirect treatment comparisons and network meta-analysis for health-care decision making: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 1. Value Health. Jun. 2011;14(4):417-28. [pmid: 21669366].
2 Hoaglin DC, Hawkins N, Jansen JP, et al. Conducting indirect-treatment-comparison and network-meta-analysis studies: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 2. Value Health. Jun. 2011;14(4):429-37. [pmid: 21669367].
3 Ades AE, Caldwell DM, Reken S, et al. NICE DSU Technical Support Document 7: Evidence Synthesis of Treatment Efficacy in Decision Making: A Reviewer's Checklist. United Kingdom. 2012. www.nicedsu.org.uk/TSD7%20reviewer%20checklist.final.08.05.12.pdf. August 23, 2012.
4 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
5 Smith TC, Spiegelhalter DJ, Thomas A. Bayesian approaches to random-effects meta-analysis: a comparative study. Stat Med. Dec. 30. 1995;14(24):2685-99. [pmid: 8619108].
6 Nixon RM, Bansback N, Brennan A. Using mixed treatment comparisons and meta-regression to perform indirect comparisons to estimate the efficacy of biologic treatments in rheumatoid arthritis. Stat Med. Mar. 15. 2007;26(6):1237-54. [pmid: 16900557].
7 Lu G, Ades A. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
8 Lu G, Ades A. Assessing evidence inconsistency in Mixed Treatment Comparisons. J Am Stat Assoc. 2006;101:447-59.
9 Jansen JP, Crawford B, Bergman G, et al. Bayesian meta-analysis of multiple treatment comparisons: an introduction to mixed treatment comparisons. Value Health. Sep-Oct. 2008;11(5):956-64. [pmid: 18489499].
10 Dias S, Welton NJ, Sutton AJ, et al. NICE DSU Technical Support Document 2: A Generalised Linear Modelling Framework for Pairwise and Network Meta-Analysis of Randomised Controlled Trials. United Kingdom. 2011. (last updated April 2012). www.nicedsu.org.uk/TSD2%20General%20meta%20analysis.final.08.05.12.pdf. August 23, 2012.
11 Welton NJ, Cooper NJ, Ades AE, et al. Mixed treatment comparison with multiple outcomes reported inconsistently across trials: evaluation of antivirals for treatment of influenza A and B. Stat Med. Nov. 29. 2008;27(27):5620-39. [pmid: 18680174].
12 Shamliyan TA, Wang SY, Olson-Kellogg B, et al. Physical Therapy for Knee Pain Secondary to Osteoarthritis Comparative Effectiveness Review. Prepared by the Minnesota Evidence-based Practice Center under Contract No 290-1007-10064 I. Agency for Healthcare Research and Quality. Rockville, MD. In press.
13 Ades AE, Mavranezouli I, Dias S, et al. Network meta-analysis with competing risk outcomes. Value Health. Dec. 2010;13(8):976-83. [pmid: 20825617].
14 Franchini AJ, Dias S, Ades AE, et al. Accounting for correlation in network meta-analysis with multi-arm trials. Research Synthesis Methods. 2012;3(2):142-60.
15 Little RJ, Rubin DB. Statistical Analysis with Missing Data. 2nd Edition. New York. Wiley. 2002.
16 Bullens PHJ, van Loon CJM, de Waal Malefijt MC, et al. Patient satisfaction after total knee arthroplasty. J Arthroplasty. Sept. 2001;16(6):740-7. [pmid: 11547372].
17 Roos EM, Toksvig-Larsen S. Knee injury and Osteoarthritis Outcome Score (KOOS) - validation and comparison to the WOMAC in total knee replacement. Health Qual Life Outcomes. 2003;1:17. [pmid: 12801417].
18 Roos EM, Lohmander LS. The Knee injury and Osteoarthritis Outcome Score (KOOS): from joint injury to osteoarthritis. Health Qual Life Outcomes. 2003;1:64. [pmid: 14613558].
19 Jackson D, Riley R, White IR. Multivariate meta-analysis: Potential and promise. Stat Med. 2011. Jan. 26. [pmid: 21268052].
20 Lu G, Ades A. Modeling between-trial variance structure in mixed treatment comparisons. Biostatistics. Oct. 2009;10(4):792-805. [pmid: 19687150].
21 Salanti G, Higgins JP, Ades AE, et al. Evaluation of networks of randomized trials. Stat Methods Med Res. Jun. 2008;17(3):279-301. [pmid: 17925316].
22 Carlin BP, Louis TA. Bayesian Methods for Data Analysis. 3rd ed. Boca Raton, FL. Chapman & Hall/CRC. 2009.
23 Spiegelhalter DJ, Best NG, Carlin BP, et al. Bayesian measures of model complexity and fit. J R Stat Soc Series B Stat Methodol. 2002;64(4):583-639.
24 Celeux G, Forbes F, Robert C, et al. Deviance information criteria for missing data models. Bayesian Analysis 1. 2006;1:651-706.
25 Salanti G, Ades AE, Ioannidis JP. Graphical methods and numerical summaries for presenting results from multiple-treatment meta-analysis: an overview and tutorial. J Clin Epidemiol. Feb. 2011;64(2):163-71. [pmid: 20688472].
26 Gelman A. Running WinBugs and OpenBugs from R. www.stat.columbia.edu/∼gelman/bugsR/runningbugs.html. 2007. April 2012.
27 Lunn DJ, Thomas A, Best N, et al. WinBUGS—a Bayesian modeling framework: concepts, structure, and extensibility. Stat Comput. 2000;10(4):325-37.
28 Aglamis B, Toraman NF, Yaman H. The effect of a 12-week supervised multicomponent exercise program on knee OA in Turkish women. J Back Musculoskelet Rehabil. 2008;21(2):121-8.
29 Kovar PA, Allegrante JP, MacKenzie CR, et al. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Ann Intern Med. Apr. 1. 1992;116(7):529-34. [pmid: 1543305].
30 Ettinger WH Jr., Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). JAMA. 1997;277(1):25-31. [pmid: 8980206].
31 Sullivan T, Allegrante JP, Peterson MG, et al. One-year followup of patients with osteoarthritis of the knee who participated in a program of supervised fitness walking and supportive patient education. Arthritis Care Res. Aug. 1998;11(4):228-33. [pmid: 9791321].
32 Patrick DL, Ramsey SD, Spencer AC, et al. Economic evaluation of aquatic exercise for persons with osteoarthritis. Med Care. May. 2001;39(5):413-24. [pmid: 11317090].
33 Baker KR, Nelson ME, Felson DT, et al. The efficacy of home based progressive strength training in older adults with knee osteoarthritis: a randomized controlled trial. J Rheumatol. Jul. 2001;28(7):1655-65. [pmid: 11469475].
34 Kuptniratsaikul V, Tosayanonda O, Nilganuwong S, et al. The efficacy of a muscle exercise program to improve functional performance of the knee in patients with osteoarthritis. J Med Assoc Thai. Jan. 2002;85(1):33-40. [pmid: 12075718].
35 Callaghan MJ, Whittaker PE, Grimes S, et al. An evaluation of pulsed shortwave on knee osteoarthritis using radioleucoscintigraphy: a randomised, double blind, controlled trial. Joint Bone Spine. Mar. 2005;72(2):150-5. [pmid: 15797496].
36 Laufer Y, Zilberman R, Porat R, et al. Effect of pulsed short-wave diathermy on pain and function of subjects with osteoarthritis of the knee: a placebo-controlled double-blind clinical trial. Clin Rehabil. May. 2005;19(3):255-63. [pmid: 15859526].
37 Yip YB, Sit JW, Fung KK, et al. Impact of an arthritis self-management programme with an added exercise component for osteoarthritic knee sufferers on improving pain, functional outcomes, and use of health care services: An experimental study. Patient Educ Couns. Jan. 2007;65(1):113-21. [pmid: 17010554].
38 Rooks DS, Huang J, Bierbaum BE, et al. Effect of preoperative exercise on measures of functional status in men and women undergoing total hip and knee arthroplasty. Arthritis Rheum. Oct. 15. 2006;55(5):700-8. [pmid: 17013852].
39 Brismee JM, Paige RL, Chyu MC, et al. Group and home-based tai chi in elderly subjects with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. Feb. 2007;21(2):99-111. [pmid: 17264104].
40 Garland D, Holt P, Harrington JT, et al. A 3-month, randomized, double-blind, placebo-controlled study to evaluate the safety and efficacy of a highly optimized, capacitively coupled, pulsed electrical stimulator in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Jun. 2007;15(6):630-7. [pmid: 17303443].
41 Doi T, Akai M, Fujino K, et al. Effect of home exercise of quadriceps on knee osteoarthritis compared with nonsteroidal antiinflammatory drugs: a randomized controlled trial. Am J Phys Med Rehabil. 2008;87(4):258-69. [pmid: 18356618].
42 Lund H, Weile U, Christensen R, et al. A randomized controlled trial of aquatic and land-based exercise in patients with knee osteoarthritis. J Rehabil Med. Feb. 2008;40(2):137-44. [pmid: 18509579].
43 Yip YB, Sit JW, Wong DY, et al. A 1-year follow-up of an experimental study of a self-management arthritis programme with an added exercise component of clients with osteoarthritis of the knee. Psychol Health Med. 2008;13(4):402-14. [pmid: 18825579].
44 Özgönenel L, Aytekin E, Durmusoglu G. A double-blind trial of clinical effects of therapeutic ultrasound in knee osteoarthritis. Ultrasound Med Biol. Jan. 2009;35(1):44-9. [pmid: 18829151].
45 Selfe TK, Bourguignon C, Taylor AG. Effects of noninvasive interactive neurostimulation on symptoms of osteoarthritis of the knee: a randomized, sham-controlled pilot study. J Altern Complement Med. 2008;14(9):1075-81. [pmid: 19055333].
46 Péloquin L, Bravo G, Gauthier P, et al. Effects of a cross-training exercise program in persons with osteoarthritis of the knee a randomized controlled trial. J Clin Rheumatol. Jun. 1999;5(3):126-36. [pmid: 19078371].
47 Chaipinyo K, Karoonsupcharoen O. No difference between home-based strength training and home-based balance training on pain in patients with knee osteoarthritis: a randomised trial. Aust J Physiother. 2009;55(1):25-30. [pmid: 19226239].
48 Lee HJ, Park HJ, Chae Y, et al. Tai Chi Qigong for the quality of life of patients with knee osteoarthritis: a pilot, randomized, waiting list controlled trial. Clin Rehabil. 2009;23(6):504-11. [pmid: 19389743].
49 Tascioglu F, Kuzgun S, Armagan O, et al. Short-term effectiveness of ultrasound therapy in knee osteoarthritis. J Int Med Res. Jul-Aug. 2010;38(4):1233-42. [pmid: 20925995].
50 Fukuda TY, Alves da Cunha R, Fukuda VO, et al. Pulsed shortwave treatment in women with knee osteoarthritis: a multicenter, randomized, placebo-controlled clinical trial. Phys Ther. Jul. 2011;91(7):1009-17. [pmid: 21642511].
51 Messier SP, Thompson CD, Ettinger WH. Effects of long-term aerobic or weight training regimes on gait in an older, osteoarthritic population. J Appl Biomech. 1997;13(2):205-25.
52 Grimmer K. A controlled double blind study comparing the effects of strong burst mode TENS and high rate TENS on painful osteoarthritic knees. Aust J Physiother. 1992;38(1):49-56.
53 Taylor P, Hallett M, Flaherty L. Treatment of osteoarthritis of the knee with transcutaneous electrical nerve stimulation. Pain. Oct. 1981;11(2):233-40. [pmid: 7033891].
54 Borjesson M, Robertson E, Weidenhielm L, et al. Physiotherapy in knee osteoarthrosis: effect on pain and walking. Physiother Res Int. 1996;1(2):89-97. [pmid: 9238726].
55 Bautch JC, Malone DG, Vailas AC. Effects of exercise on knee joints with osteoarthritis: a pilot study of biologic markers. Arthritis Care Res. Feb. 1997;10(1):48-55. [pmid: 9313390].
56 Wyatt FB, Milam S, Manske RC, et al. The effects of aquatic and traditional exercise programs on persons with knee osteoarthritis. J Strength Cond Res. 2001;15(3):337-40. [pmid: 11710661].
57 Gür H, Cakin N, Akova B, et al. Concentric versus combined concentric-eccentric isokinetic training: effects on functional capacity and symptoms in patients with osteoarthrosis of the knee. Arch Phys Med Rehabil. Mar. 2002;83(3):308-16. [pmid: 11887109].
58 Topp R, Woolley S, Hornyak J 3rd, et al. The effect of dynamic versus isometric resistance training on pain and functioning among adults with osteoarthritis of the knee. Arch Phys Med Rehabil. Sep. 2002;83(9):1187-95. [pmid: 12235596].
59 Talbot LA, Gaines JM, Huynh TN, et al. A home-based pedometer-driven walking program to increase physical activity in older adults with osteoarthritis of the knee: a preliminary study. J Am Geriatr Soc. Mar. 2003;51(3):387-92. [pmid: 12588583].
60 Talbot LA, Gaines JM, Ling SM, et al. A home-based protocol of electrical muscle stimulation for quadriceps muscle strength in older adults with osteoarthritis of the knee. J Rheumatol. Jul. 2003;30(7):1571-8. [pmid: 12858461].
61 Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. May. 2004;50(5):1501-10. [pmid: 15146420].
62 Keefe FJ, Blumenthal J, Baucom D, et al. Effects of spouse-assisted coping skills training and exercise training in patients with osteoarthritic knee pain: a randomized controlled study. Pain. Aug. 2004;110(3):539-49. [pmid: 15288394].
63 Gaines JM, Metter EJ, Talbot LA. The effect of neuromuscular electrical stimulation on arthritis knee pain in older adults with osteoarthritis of the knee. Appl Nurs Res. Aug. 2004;17(3):201-6. [pmid: 15343554].
64 Law PP, Cheing GL. Optimal stimulation frequency of transcutaneous electrical nerve stimulation on people with knee osteoarthritis. J Rehabil Med. Sep. 2004;36(5):220-5. [pmid: 15626162].
65 Durmus D, Alayli G, Canturk F. Effects of quadriceps electrical stimulation program on clinical parameters in the patients with knee osteoarthritis. Clin Rheumatol. May. 2007;26(5):674-8. [pmid: 16897119].
66 Hay EM, Foster NE, Thomas E, et al. Effectiveness of community physiotherapy and enhanced pharmacy review for knee pain in people aged over 55 presenting to primary care: pragmatic randomised trial. BMJ. Nov. 11. 2006;333(7576):995. [pmid: 17056608].
67 Silva LE, Valim V, Pessanha AP, et al. Hydrotherapy versus conventional land-based exercise for the management of patients with osteoarthritis of the knee: a randomized clinical trial. Physical Therapy. 2008;88(1):12-21. [pmid: 17986497].
68 Jan MH, Lin JJ, Liau JJ, et al. Investigation of clinical effects of high- and low-resistance training for patients with knee osteoarthritis: a randomized controlled trial. Phys Ther. 2008;88(4):427-36. [pmid: 18218827].
69 Itoh K, Hirota S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation (TENS) to treat knee osteoarthritis (OA). Chin Med. 2008;3:2. [pmid: 18312661].
70 An B, Dai K, Zhu Z, et al. Baduanjin alleviates the symptoms of knee osteoarthritis. J Altern Complement Med. Mar. 2008;14(2):167-74. [pmid: 18315512].
71 Tsauo JY, Cheng PF, Yang RS. The effects of sensorimotor training on knee proprioception and function for patients with knee osteoarthritis: a preliminary report. Clin Rehabil. 2008;22(5):448-57. [pmid: 18441041].
72 Lim BW, Hinman RS, Wrigley TV, et al. Does knee malalignment mediate the effects of quadriceps strengthening on knee adduction moment, pain, and function in medial knee osteoarthritis? A randomized controlled trial. Arthritis Rheum. 2008;59(7):943-51. [pmid: 18576289].
73 Pietrosimone BG, Hart JM, Saliba SA, et al. Immediate effects of transcutaneous electrical nerve stimulation and focal knee joint cooling on quadriceps activation. Med Sci Sports Exerc. Jun. 2009;41(6):1175-81. [pmid: 19461552].
74 Lin DH, Lin CH, Lin YF, et al. Efficacy of 2 non-weight-bearing interventions, proprioception training versus strength training, for patients with knee osteoarthritis: a randomized clinical trial. J Orthop Sports Phys Ther. 2009;39(6):450-7. [pmid: 19531879].
75 Weng MC, Lee CL, Chen CH, et al. Effects of different stretching techniques on the outcomes of isokinetic exercise in patients with knee osteoarthritis. Kaohsiung J Med Sci. 2009;25(6):306-15. [pmid: 19560995].
76 Farr JN, Going SB, McKnight PE, et al. Progressive resistance training improves overall physical activity levels in patients with early osteoarthritis of the knee: a randomized controlled trial. Phys Ther. Mar. 2010;90(3):356-66. [pmid: 20056719].
77 Bennell KL, Hunt MA, Wrigley TV, et al. Hip strengthening reduces symptoms but not knee load in people with medial knee osteoarthritis and varus malalignment: a randomised controlled trial. Osteoarthritis Cartilage. May. 18. 2010;(5):621-8. Epub 2010 Feb 6.(5):621-8. [pmid: 20175973].
78 Swank AM, Kachelman JB, Bibeau W, et al. Prehabilitation before total knee arthroplasty increases strength and function in older adults with severe osteoarthritis. J Strength Cond Res. Feb. 2011;25(2):318-25. [pmid: 21217530].
79 Schilke JM, Johnson GO, Housh TJ, et al. Effects of muscle-strength training on the functional status of patients with osteoarthritis of the knee joint. Nurs Res. Mar-Apr. 1996;45(2):68-72. [pmid: 8604366].
80 Deyle GD, Henderson NE, Matekel RL, et al. Effectiveness of manual physical therapy and exercise in osteoarthritis of the knee. A randomized, controlled trial. Ann Intern Med. 2000;132(3):173-81. [pmid: 10651597].
81 Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychol. 2002;21(5):419-26. [pmid: 12211508].
82 Riley RD, Abrams KR, Lambert PC, et al. An evaluation of bivariate random-effects meta-analysis for the joint synthesis of two correlated outcomes. Stat Med. Jan. 15. 2007;26(1):78-97. [pmid: 16526010].
83 Whitehead A. Meta-Analysis of Controlled Clinical Trials. John Wiley. 2002.
84 Simmonds MC, Higgins JP. Covariate heterogeneity in meta-analysis: criteria for deciding between meta-regression and individual patient data. Stat Med. Jul. 10. 2007;26(15):2982-99. [pmid: 17195960].
85 Lu G, Ades AE, Sutton AJ, et al. Meta-analysis of mixed treatment comparisons at multiple follow-up times. Stat Med. Sep. 10. 2007;26(20):3681-99. [pmid: 17285571].
86 Terasawa T, Trikalinos NA, Djulbegovic B, et al. Comparative efficacy of first-line therapies for advanced-stage chronic lymphocytic leukemia: A multiple-treatment meta-analysis. Cancer Treat Rev. 2012. Jun. 13. [pmid: 22703832].