# Methods

## OA Data

We reviewed publications in English after 1979 that examined physical therapy interventions for community dwelling adults with knee pain secondary to osteoarthritis. A total of 4,266 references were retrieved.12 After screening out studies that contained no eligible exposure, target population, outcomes, or associative hypothesis tested, 422 references were included in our review. Knee pain, disability, quality of life, and functional outcomes after physical therapy interventions were reported in 193 RCTs; 84 of those met the study inclusion/exclusion criteria given in the next paragraph. Because definitions of physical therapy interventions and outcomes varied dramatically among studies, only a small proportion of comparisons met these criteria.

Inclusion/exclusion criteria involved the following aspects. First, comparators should include no active treatment, usual care (education), sham stimulation (placebo), or other therapy intervention (that is, active-active trials were not excluded). Eligible patient-centered outcomes were knee pain, disability, quality of life, perceived health status, and global assessments of treatment effectiveness. The target population was adults with knee pain secondary to knee osteoarthritis in outpatient settings, including home-based therapy. Chronic OA was defined as meeting diagnostic criteria and having symptoms of OA for >2 months. We excluded populations with knee OA who had knee arthroplasty on the “study limb” within 6 months before the study, osteonecrosis, acute knee injuries, inflammatory arthritis, arthritis secondary to systemic disease, and physical therapy treatment combined with drug treatments. Since all included studies are applied to the same inclusion and exclusion criteria, we assume that all populations are similar to each other.

For the present analysis, we selected the pain and disability outcomes as primary and secondary outcomes, respectively, resulting in the inclusion of 54 RCTs. Table 1 displays the data from these 54 RCTs, comprising aggregated continuous outcomes (sample mean and standard deviation [SD]) measuring the level of pain and disability after physical therapies using various standard scores. The OA data compare eight physical therapies (low intensity diathermy, high intensity diathermy, electrical stimulation, aerobic exercise, aquatic exercise, strength exercise, proprioception exercise, and ultrasound treatment) and three reference therapies (no treatment, placebo, and education). Under proprioception exercise, we also included tai chi and balance exercise. Most studies reported treatment outcomes at a single followup time, but when a study investigated outcomes at multiple followup times, we selected the one most commonly reported for that treatment. To measure the pain outcome, the Western Ontario MacMaster (WOMAC), Visual Analogue Scale (VAS), Arthritis Impact Measurement Scale (AIMS), and other standard scores were used. For the disability outcome, the measurement tools included the WOMAC total, Medical Outcome Study (MOS) 36-Item Short-Form Health Survey (SF-36 physical function), AIMS, Health Assessment Questionnaire (HAQ), and Knee Injury and Osteoarthritis Outcome Score (KOOS). Although these scores do not share the same scale and differ in a few details, in general they do measure outcomes equivalently, and all of their scales cover the same qualitative ranges (from “no pain” to “extreme pain” for pain measurements, and from “no impairment” to “profound impairment” for disability). The scores they yield also tend to be highly correlated when reported for the same subjects.16-18 Because the scores' different scales make their values incomparable, we rescaled the mean scores to range from 0 to 10, where small values indicate better condition, and called this the rescaled score. We also recalculated the SDs based on the transformation of the mean score, and call this the rescaled SD. We remark that we have no reason to doubt the appropriation of linear retransformation here, but our methods apply equally well under nonlinear transformations if more appropriate clinically.

Table 1 Raw OA data

Study | Country | Duration | Pain Score | Disability Score | N | Therapy | Pain Rescaled Score | Pain Rescaled SD | Disability Rescaled Score | Disability Rescaled SD
Aglamis, 2008^28^ | Turkey | 2 | VAS 0-10 | SF36 0-100 | 17 | No trt. | 7.700 | 2.300 | 6.360 | 0.790
Aglamis, 2008^28^ | Turkey | 2 | VAS 0-10 | SF36 0-100 | 17 | Ex. aerobic | 0.700 | 1.000 | 1.280 | 0.970
Kovar, 1992^29^ | US | 2 | AIMS 0-10 | AIMS 0-10 | 50 | No trt. | 4.770 | 2.120 | 5.960 | 2.320
Kovar, 1992^29^ | US | 2 | AIMS 0-10 | AIMS 0-10 | 52 | Ex. aerobic | 3.770 | 1.730 | 3.740 | 2.690
Ettinger, 1997^30^ | US | 4 | Other^a^ 1-6 | Other^b^ 1-5 | 149 | Education | 2.800 | 1.220 | 2.250 | 1.225
Ettinger, 1997^30^ | US | 4 | Other^a^ 1-6 | Other^b^ 1-5 | 144 | Ex. aerobic | 2.280 | 1.200 | 1.800 | 1.200
Ettinger, 1997^30^ | US | 4 | Other^a^ 1-6 | Other^b^ 1-5 | 146 | Ex. strength | 2.420 | 1.440 | 1.850 | 1.225
Sullivan, 1998^31^ | US | 4 | AIMS 0-10 | AIMS 0-10 | 50 | Education | 5.500 | 2.070 | 6.180 | 2.750
Sullivan, 1998^31^ | US | 4 | AIMS 0-10 | AIMS 0-10 | 52 | Ex. aerobic | 4.590 | 2.400 | 6.070 | 2.950
Patrick, 2001^32^ | US | 2 | HAQ 0-3 | HAQ 0-3 | 124 | No trt. | 4.873 | 2.063 | 3.757 | 2.237
Patrick, 2001^32^ | US | 2 | HAQ 0-3 | HAQ 0-3 | 125 | Ex. aquatic | 4.607 | 2.457 | 3.110 | 1.833
Baker, 2001^33^ | US | 3 | WOMAC 0-500 | SF36 0-100 | 23 | Education | 3.780 | 2.345 | 3.920 | 2.936
Baker, 2001^33^ | US | 3 | WOMAC 0-500 | SF36 0-100 | 23 | Ex. strength | 2.560 | 1.962 | 3.660 | 2.869
Kuptniratsaikul, 2002^34^ | Thailand | 3 | AIMS 0-10 | Other^c^ 0-20 | 193 | No trt. | 5.070 | 2.530 | 3.045 | 1.720
Kuptniratsaikul, 2002^34^ | Thailand | 3 | AIMS 0-10 | Other^c^ 0-20 | 199 | Ex. strength | 4.060 | 2.530 | 2.695 | 1.805
Callaghan, 2005^35^ | UK | 1 | VAS 0-10 | AIMS 0-10 | 10 | Placebo | 6.300 | 1.900 | 5.100 | 1.700
Callaghan, 2005^35^ | UK | 1 | VAS 0-10 | AIMS 0-10 | 10 | Diathermy(L) | 5.000 | 3.200 | 5.500 | 3.000
Callaghan, 2005^35^ | UK | 1 | VAS 0-10 | AIMS 0-10 | 10 | Diathermy(H) | 5.500 | 2.700 | 5.100 | 2.300
Laufer, 2005^36^ | Israel | 1 | WOMAC 0-10 | WOMAC 0-10 | 33 | Placebo | 4.440 | 3.510 | 4.630 | 3.540
Laufer, 2005^36^ | Israel | 1 | WOMAC 0-10 | WOMAC 0-10 | 38 | Diathermy(L) | 4.730 | 3.480 | 4.930 | 3.630
Laufer, 2005^36^ | Israel | 1 | WOMAC 0-10 | WOMAC 0-10 | 32 | Diathermy(H) | 4.030 | 3.300 | 4.400 | 3.440
Yip, 2007^37^ | China | 3 | VAS 0-10 | HAQ 0-24 | 94 | No trt. | 4.250 | 2.367 | 1.850 | 1.374
Yip, 2007^37^ | China | 3 | VAS 0-10 | HAQ 0-24 | 88 | Ex. aerobic | 3.858 | 2.201 | 1.958 | 1.539
Rooks, 2006^38^ | US | 2 | WOMAC 0-30 | SF36 0-100 | 23 | Education | 3.750 | 2.500 | 5.980 | 1.940
Rooks, 2006^38^ | US | 2 | WOMAC 0-30 | SF36 0-100 | 22 | Ex. aquatic | 3.650 | 0.350 | 6.600 | 2.150
Brismee, 2007^39^ | US | 2 | Other^d^ 0-10 | WOMAC 26-130 | 19 | No trt. | 3.370 | 1.780 | 2.990 | 1.630
Brismee, 2007^39^ | US | 2 | Other^d^ 0-10 | WOMAC 26-130 | 22 | Ex. prop. | 2.410 | 2.050 | 2.806 | 2.327
Garland, 2007^40^ | US | 2 | WOMAC 0-100 | WOMAC 0-100 | 19 | Placebo | 4.180 | 1.659 | 4.590 | 1.681
Garland, 2007^40^ | US | 2 | WOMAC 0-100 | WOMAC 0-100 | 39 | Elec. stim. | 3.740 | 2.360 | 3.960 | 2.425
Doi, 2008^41^ | Japan | 2 | VAS 0-10 | SF36 0-100 | 70 | No trt. | 2.959 | 2.394 | 3.660 | 1.636
Doi, 2008^41^ | Japan | 2 | VAS 0-10 | SF36 0-100 | 72 | Ex. strength | 2.255 | 2.068 | 2.881 | 1.633
Lund, 2008^42^ | Denmark | 2 | VAS 0-10 | KOOS 0-100 | 27 | No trt. | 2.380 | 1.403 | 3.860 | 1.351
Lund, 2008^42^ | Denmark | 2 | VAS 0-10 | KOOS 0-100 | 27 | Ex. aquatic | 1.810 | 1.403 | 3.700 | 1.351
Lund, 2008^42^ | Denmark | 2 | VAS 0-10 | KOOS 0-100 | 25 | Ex. strength | 1.560 | 1.400 | 3.610 | 1.350
Yip, 2008^43^ | Hong Kong | 3 | VAS 0-10 | HAQ 0-100 | 50 | No trt. | 3.459 | 2.355 | 0.357 | 0.280
Yip, 2008^43^ | Hong Kong | 3 | VAS 0-10 | HAQ 0-100 | 45 | Ex. aerobic | 3.523 | 2.193 | 0.428 | 0.368
Özgönenel, 2009^44^ | Turkey | 1 | VAS 0-10 | WOMAC 0-96 | 33 | Placebo | 4.000 | 2.600 | 4.010 | 1.583
Özgönenel, 2009^44^ | Turkey | 1 | VAS 0-10 | WOMAC 0-96 | 34 | Ultra sound | 3.900 | 2.000 | 3.469 | 1.615
Selfe, 2008^45^ | US | 2 | WOMAC 0-50 | WOMAC 0-240 | 20 | Placebo | 3.178 | 1.784 | 3.420 | 1.654
Selfe, 2008^45^ | US | 2 | WOMAC 0-50 | WOMAC 0-240 | 20 | Elec. stim. | 2.834 | 2.136 | 2.933 | 2.034
Péloquin, 1999^46^ | Canada | 2 | AIMS 0-10 | AIMS 0-10 | 68 | Education | 3.940 | 2.220 | 1.930 | 1.880
Péloquin, 1999^46^ | Canada | 2 | AIMS 0-10 | AIMS 0-10 | 69 | Ex. aerobic | 3.090 | 1.540 | 1.850 | 2.260
Chaipinyo, 2009^47^ | US | 2 | KOO 0-100 | KOOS 0-100 | 24 | Ex. strength | 1.800 | 1.600 | 1.800 | 1.300
Chaipinyo, 2009^47^ | US | 2 | KOO 0-100 | KOOS 0-100 | 24 | Ex. prop. | 1.300 | 1.200 | 1.200 | 1.000
Lee, 2009^48^ | South Korea | 2 | WOMAC 0-35 | SF36 0-100 | 15 | No trt. | 1.686 | 1.057 | 4.490 | 1.750
Lee, 2009^48^ | South Korea | 2 | WOMAC 0-35 | SF36 0-100 | 29 | Ex. prop. | 1.314 | 1.143 | 3.560 | 2.090
Tascioglu, 2010^49^ | Turkey | 1 | VAS 0-10 | WOMAC 0-96 | 30 | Placebo | 6.670 | 1.780 | 4.618 | 1.331
Tascioglu, 2010^49^ | Turkey | 1 | VAS 0-10 | WOMAC 0-96 | 30 | Ultra sound | 5.250 | 1.900 | 4.525 | 1.717
Fukuda, 2011^50^ | Brazil | 1 | Other^e^ 0-10 | KOOS 0-100 | 23 | Placebo | 6.900 | 2.000 | 4.850 | 1.750
Fukuda, 2011^50^ | Brazil | 1 | Other^e^ 0-10 | KOOS 0-100 | 32 | Diathermy(L) | 3.800 | 2.200 | 3.850 | 2.030
Fukuda, 2011^50^ | Brazil | 1 | Other^e^ 0-10 | KOOS 0-100 | 31 | Diathermy(H) | 4.600 | 2.500 | 3.680 | 1.650
Messier, 1997^51^ | US | 3 | Other^f^ 1-6 | | 36 | Education | 2.560 | 1.800
Messier, 1997^51^ | US | 3 | Other^f^ 1-6 | | 33 | Ex. aerobic | 2.300 | 1.954
Grimmer, 1992^52^ | Australia | 1 | VAS 0-10 | | 20 | Placebo | 3.500 | 2.900
Grimmer, 1992^52^ | Australia | 1 | VAS 0-10 | | 20 | Elec. stim. | 2.200 | 2.800
Taylor, 1981^53^ | US | 1 | Other^g^ -1-3 | | 10 | Placebo | 6.750 | 2.375
Taylor, 1981^53^ | US | 1 | Other^g^ -1-3 | | 10 | Elec. stim. | 5.250 | 1.425
Borjesson, 1996^54^ | Sweden | 2 | Other^h^ 0-10 | | 34 | No trt. | 3.300 | 1.500
Borjesson, 1996^54^ | Sweden | 2 | Other^h^ 0-10 | | 34 | Ex. strength | 3.000 | 1.500
Bautch, 1997^55^ | US | 2 | VAS 0-10 | | 17 | Education | 2.080 | 2.090
Bautch, 1997^55^ | US | 2 | VAS 0-10 | | 17 | Ex. aerobic | 2.190 | 1.670
Wyatt, 2001^56^ | US | 2 | VAS 0-10 | | 23 | Ex. aerobic | 3.800 | 1.600
Wyatt, 2001^56^ | US | 2 | VAS 0-10 | | 23 | Ex. aquatic | 2.400 | 1.600
Gür, 2002^57^ | Turkey | 2 | Other^i^ 0-70 | | 6 | No trt. | 4.000 | 0.743
Gür, 2002^57^ | Turkey | 2 | Other^i^ 0-70 | | 9 | Ex. strength | 1.471 | 0.643
Topp, 2002^58^ | US | 3 | WOMAC 0-20 | | 35 | No trt. | 5.385 | 1.528
Topp, 2002^58^ | US | 3 | WOMAC 0-20 | | 32 | Ex. strength | 5.190 | 1.657
Talbot, 2003^59^ | US | 3 | Other^j^ 0-78 | | 21 | Education | 1.397 | 1.242
Talbot, 2003^59^ | US | 3 | Other^j^ 0-78 | | 19 | Ex. aerobic | 1.660 | 1.463
Talbot, 2003^60^ | US | 2 | Other^j^ 0-78 | | 18 | Education | 1.426 | 1.026
Talbot, 2003^60^ | US | 2 | Other^j^ 0-78 | | 20 | Elec. stim. | 2.094 | 1.712
Messier, 2004^61^ | US | 3 | WOMAC 0-20 | | 78 | No trt. | 3.095 | 2.030
Messier, 2004^61^ | US | 3 | WOMAC 0-20 | | 82 | Education | 2.550 | 1.945
Messier, 2004^61^ | US | 3 | WOMAC 0-20 | | 80 | Ex. aerobic | 3.110 | 2.010
Keefe, 2004^62^ | US | 2 | AIMS 0-10 | | 18 | No trt. | 4.030 | 2.080
Keefe, 2004^62^ | US | 2 | AIMS 0-10 | | 18 | Education | 4.000 | 1.560
Keefe, 2004^62^ | US | 2 | AIMS 0-10 | | 16 | Ex. aerobic | 3.190 | 1.850
Gaines, 2004^63^ | US | 2 | AIMS 0-10 | | 18 | Education | 5.990 | 2.400
Gaines, 2004^63^ | US | 2 | AIMS 0-10 | | 20 | Elec. stim. | 5.180 | 2.110
Law, 2004^64^ | Hong Kong | 1 | VAS 0-10 | | 10 | Placebo | 4.100 | 2.600
Law, 2004^64^ | Hong Kong | 1 | VAS 0-10 | | 12 | Elec. stim. | 0.700 | 0.700
Durmus, 2007^65^ | Turkey | 1 | Other^i^ 0-10 | | 25 | Elec. stim. | 0.600 | 0.100
Durmus, 2007^65^ | Turkey | 1 | Other^i^ 0-10 | | 25 | Ex. strength | 1.040 | 0.270
Hay, 2006^66^ | UK | 3 | WOMAC 0-20 | | 108 | No trt. | 4.180 | 1.950
Hay, 2006^66^ | UK | 3 | WOMAC 0-20 | | 109 | Ex. aerobic | 3.755 | 2.400
Silva, 2008^67^ | Brazil | 2 | VAS 0-10 | | 32 | Ex. aerobic | 3.840 | 2.750
Silva, 2008^67^ | Brazil | 2 | VAS 0-10 | | 32 | Ex. aquatic | 3.700 | 1.810
Jan, 2008^68^ | Taiwan | 2 | WOMAC 0-20 | | 34 | No trt. | 3.550 | 1.700
Jan, 2008^68^ | Taiwan | 2 | WOMAC 0-20 | | 34 | Ex. strength | 2.400 | 1.750
Itoh, 2008^69^ | Japan | 2 | VAS 0-10 | | 8 | No trt. | 4.930 | 2.020
Itoh, 2008^69^ | Japan | 2 | VAS 0-10 | | 8 | Elec. stim. | 5.350 | 0.970
An, 2008^70^ | China | 2 | WOMAC 0-500 | | 14 | No trt. | 2.764 | 2.252
An, 2008^70^ | China | 2 | WOMAC 0-500 | | 14 | Ex. aerobic | 1.422 | 2.202
Tsauo, 2008^71^ | Taiwan | 2 | WOMAC 0-500 | | 30 | No trt. | 1.320 | 0.760
Tsauo, 2008^71^ | Taiwan | 2 | WOMAC 0-500 | | 30 | Ex. prop. | 1.280 | 0.740
Lim, 2008^72^ | Australia | 2 | WOMAC 0-100 | | 28 | No trt. | 3.360 | 1.540
Lim, 2008^72^ | Australia | 2 | WOMAC 0-100 | | 27 | Ex. strength | 2.280 | 1.690
Pietrosimone, 2009^73^ | US | 1 | VAS 0-10 | | 12 | No trt. | 2.096 | 1.844
Pietrosimone, 2009^73^ | US | 1 | VAS 0-10 | | 11 | Elec. stim. | 1.165 | 1.671
Lin, 2009^74^ | Taiwan | 2 | WOMAC 0-20 | | 36 | No trt. | 3.650 | 1.700
Lin, 2009^74^ | Taiwan | 2 | WOMAC 0-20 | | 36 | Ex. strength | 2.100 | 1.500
Lin, 2009^74^ | Taiwan | 2 | WOMAC 0-20 | | 36 | Ex. prop. | 2.150 | 1.150
Weng, 2009^75^ | Taiwan | 2 | VAS 0-10 | | 66 | No trt. | 4.400 | 1.400
Weng, 2009^75^ | Taiwan | 2 | VAS 0-10 | | 66 | Ex. strength | 3.600 | 0.700
Weng, 2009^75^ | Taiwan | 2 | VAS 0-10 | | 66 | Ex. prop. | 2.700 | 1.900
Farr, 2010^76^ | US | 2 | WOMAC 0-100 | | 98 | Education | 7.200 | 6.630
Farr, 2010^76^ | US | 2 | WOMAC 0-100 | | 100 | Ex. aerobic | 6.710 | 6.880
Bennell, 2010^77^ | Australia | 2 | WOMAC 0-20 | | 44 | No trt. | 3.250 | 1.650
Bennell, 2010^77^ | Australia | 2 | WOMAC 0-20 | | 45 | Ex. strength | 2.450 | 1.650
Swank, 2011^78^ | US | 2 | VAS 0-10 | | 36 | Education | 4.556 | 0.467
Swank, 2011^78^ | US | 2 | VAS 0-10 | | 37 | Ex. strength | 3.667 | 0.422
Schilke, 1996^79^ | US | 2 | | AIMS | 10 | No trt. | | | 2.500 | 0.850
| | | | 0-10 | 10 | Ex. strength | | | 2.300 | 0.840
Deyle, 2000^80^ | US | 2 | | WOMAC 0-2400 | 41 | Placebo | | | 3.893 | 2.723
Deyle, 2000^80^ | US | 2 | | WOMAC 0-2400 | 42 | Ex. aerobic | | | 1.927 | 1.826
Rejeski, 2002^81^ | US | 4 | | SF36 0-100 | 78 | Education | | | 6.559 | 0.899
Rejeski, 2002^81^ | US | 4 | | SF36 0-100 | 80 | Ex. aerobic | | | 6.286 | 1.038

Abbreviations: WOMAC = Western Ontario MacMaster; VAS = Visual Analogue Scale; AIMS = Arthritis Impact Measurement Scale; SF36 = Medical Outcome Study 36-Item Short-Form health Survey; HAQ = Health Assessment Questionnaire; KOOS = Knee Injury and Osteoarthritis Outcome Score

Note: treatment duration (followup) is the category of weeks spent in therapy (1: 0-5, 2: 6-12, 3: 13-26, and 4: >27); N is the sample size; Pain Score and Disability Scores are the scores used for pain and disability with the original ranges

a pain intensity score

b self-report of physical disability

c functional incapacity score

d overall knee pain

e numeric pain rating scale

f ambulation intensity

g subject pain

h Borg scale

I not clear

j pain rating index

Among the 54 studies, 51 measure the pain outcome, 26 measure the disability outcome, and 23 include both outcomes. Figure 1 exhibits the trial network among therapies for each outcome. The size of each node represents the number of studies investigating the therapy, and the thickness of each edge denotes the total number of samples for the relation. The numbers on the edges indicate the numbers of studies investigating the relation. For example, in the pain outcome, there are five studies investigating the relation between no treatment and proprioception exercise, but this line is thinner than the line between education and strength exercise, though it has only three studies. The network features are similar in both outcomes, but we have limited information on the disability outcome, with fewer connections between therapies and smaller total sample sizes overall than for the pain outcome.

Figure 1 Network graphs of OA data for each outcome; (a) pain and (b) disability

Note: The size of each node represents the number of studies investigating the therapy, and the thickness of each edge implies the total number of samples for the relation. The number on the line is the number of studies for the relation.

Figure 1 is a network graph depicting the relations of physical therapies among studies in the OA data for each outcome; (a) pain and (b) disability. In this figure, each therapy is listed with the proper size of node indicating the number of studies investigating the therapy, and some nodes are connected if the data include the relations. The thickness of each edge implies the total number of samples for the relation, and the number of studies for the relation is on the line. Panel (a) has thick edges between no treatment and strength exercise, no treatment and aerobic exercise, and education and aerobic exercise with more than eight studies investigating these relations. In Panel (b), the network is simpler than in the pain outcome because only about half the studies reported the disability outcome. The edges between no treatment and strength exercise, no treatment and aerobic exercise, and education and aerobic exercise are thickest with four studies examining these relations.

## Likelihood

In MTCs, we must carefully distinguish between the terms treatment and arm. The former refers to a drug or device being tested, while the latter is the data on patients randomized to a particular drug or device in a single study. We must also distinguish between reference and baseline treatments. The reference treatment is a standard control treatment (often placebo, or simply no treatment) which can be compared with other active treatments. In our OA data, we select “no treatment” as the reference treatment among three possibilities (no treatment, education, and placebo). The baseline treatment is defined as the treatment assigned to the control arm in each study. That is, each study has its own baseline treatment, which is often the same as the reference treatment, but could differ. In this report, we assume there is no inconsistency, defined as discrepancy in treatment effects arising from direct and indirect comparisons.8

Suppose we are comparing K treatments from I studies in terms of L outcomes. For the continuous outcome, we assume that the data for a specific outcome from each study follow a normal distribution. That is,

y¯_ikl_ ∼ N ( Δ_ikl_ , (σ_ikl_^2^)/(n_ikl_) ) , i = 1 , … , I , k = 1 , … , K , l = 1 , … , L ,

Where ȳ_ikl_ is the observed sample mean of the measurements, Δ_ikl_ is the unknown true population mean, σ_ikl_^2^ is the known sample variance, and n_ikl_ is the number of subjects in the k^th^ treatment arm from the i^th^ study with respect to the I^th^ continuous outcome. For the simplicity, we consider k = 1 as the reference treatment. Generally, in meta-analysis, we cannot estimate within-study correlations because we have only aggregated data.19 We assume ȳ_ikl_ are independent across arms and outcomes in study i since within-study correlations are not observed in every studies.

## Existing Lu and Ades-Style Model

### Fixed Effects Model

For meta-analysis, a fixed effects model, assuming no variability between studies, can easily be implemented. Following Lu and Ades,7, 8 the model can be written as

Δ_ikl_ = α_iBl_ if k = B , Δ_ikl_ = α_iBl_ + η_Bkl_ if k ≠ B , 1

where B indicates the baseline treatment in each study i. Here, α_iBl_ is the effect of baseline treatment and η_Bkl_ is the mean difference between treatment k and the baseline treatment (B) for outcome l in study i. However, we have to be careful to interpret α_iBl_ when the baseline treatment is not always the same. We define d_kl_ as the mean difference between treatment k and the reference treatment for outcome l, with d_1l_ = 0. Thus, η_Bkl_ can be calculated as d_kl_ − d_Bl_, and we infer the treatment effects in terms of d_kl_; that is, we assign a prior distribution to d_kl_, rather than η_Bkl_. We denote this model as the Lu and Ades (LA)-style fixed effects model (LAFE). In this approach, it is hard to interpret the baseline treatment effect α_iBl_ because not all studies have the same baseline treatment.

### Random Effects Model

Next, in order to allow variability between studies, we introduce random effects, δ_iBkl_, replacing the η_Bkl_. Specifically model (1) is respecified as

Δ_ikl_ = α_iBl_ if k = B , Δ_ikl_ = α_iBl_ + δ_iBkl_ if k ≠ B , 2

where we can assume homogeneous variance across random effects for all arms, i.e.,

δ_iBkl_ ∼ N ( d_kl_ − d_Bl_ , τ_l_^2^ ) . 3

Here, δ_iBkl_ is 0 when k = B, and τ_l_ is the standard deviation of the random effects for each outcome l. We denote this model as the Lu and Ades-style homogeneous random effects model (LAREhom). For multi-arm trials, Lu and Ades provides a between-arm-contrast correlation of 0.5, as a consequence of homogeneous variance and their consistency equation.8 The δ_iBkl_ in (3) are replaced by a vector δ_il_ that follows a multivariate normal distribution with dimension equal to the number of arms in study i minus one, for each outcome l.

## Allowing for Missing Data and Correlations Between Outcomes

### Contrast-Based Approach

We denote a model that parameterizes relative effects (e.g., the η_Bkl_ and δ_iBkl_ in (1) and (2), respectively) as a contrast-based (CB) model. Lu and Ades-style models use such a CB approach. Note that the mean effect difference between treatment k and reference treatment in terms of outcome l (d_kl_) is the parameter of interest in CB models. In MTCs it is common that the number of treatments compared in the i^th^ study is less than the complete collection of K treatments. Since each study contributes to the likelihood for a different set of treatments, using the observed measurements only can complicate estimating the covariance matrix for the δ_il_ and lead to difficulties in prior assignment and parameter inference. In addition, it is plausible that researchers select study arms based on the trials conducted previously, what statisticians call“nonignorable missingness.” In this case, ignoring the missing treatment arms can potentially lead to biased parameter estimates.15

To remedy this, we assume that all studies can in principle contain every treatment as their arms, but in practice much of this information is missing for various reasons. Under this assumption, all studies can always have a common (though possibly missing) baseline treatment, B = 1, and the distribution for the random effects δ_iBkl_ in (3) can be replaced with a matrix form as follows:

δ_il_ ∼ MVN ( d_l_ , ∑ l Trt ) , 4

Where δ_il_ = (δ_i12l_, …, δ_i1Kl_)^T^, d_l_ = (d_2l_, …, d_Kl_)^T^, and ∑ l Trt is a (K − 1) × (K − 1) unstructured covariance matrix for l = 1, …, L. Note that since δ_i11l_ and d_1l_ are always 0, they are not included in δ_il_ and d_l_. Here, ∑ l Trt captures all random contrasts' relations among treatments in each outcome l. We refer to this model as a contrast-based random effects model assuming independence between outcomes (CBRE1).

To allow correlations among outcomes, the distribution of δ_il_ in (4) needs to be respecified to

δ_ik_ ∼ MVN ( d_k_ , ∑ k Out ) , 5

where δ_ik_ = (δ_i1k1_, …, δ_i1kL_)^T^, d_k_ = (d_k1_, …, d_kL_)^T^, and ∑ k Out is a L × L unstructured covariance matrix for k = 2, …, K. In this model, we assume independent random contrasts between treatments but incorporate the correlation structure of those contrasts between outcomes through ∑ k Out . We call this model CBRE2. Alternatively, we can also use the same ∑^Out^ for all k, if such an assumption is sensible.

In this approach, we can always have the same length of vector δ_il_ or δ_ik_ in each study i, and incorporate all sources of uncertainty by considering unobserved arms as missing data to be imputed by our MCMC algorithm using Gibbs-Metropolis sampling. For example, suppose Study 1 compares treatments 1, 2, and 3, giving information about two contrasts, δ_i12l_ and δ_i13l_, whereas Study 2 compares only treatments 1 and 2, and Study 3 includes only treatments 1 and 3. We can impute the missing contrast δ_i13l_ and δ_i12l_ in Studies 2 and 3 respectively by using the information related to these contrasts observed in Study 1. The reference treatment effect, α_iBl_ in (2), is uninterpretable in this case, since each study will have different baseline treatment, as in the LA models. However, in our CB approach, α_iBl_ becomes meaningful because the baseline treatment is the same (B = 1) across all studies.

Although we only introduced the LA homogeneous random effects model, a heterogeneous random effects model can be applied with rigorous construction of covariance matrices to satisfy the positive definiteness condition under the consistency assumption.20 However, our approach does not lead to this same set of consistency equation; the imputation allows us to independently estimate all possible contrasts in every study.

### Arm-Based Approach

The CB method estimates the treatment contrasts; say, the mean difference between treatment k and the reference treatment. However, the approach's singular focus on relative treatment effects ultimately leads to many limitations. First, although we may resolve the incomparable baseline treatment problem by imputing such missing arms in our CB models, LA models still need complex model parameterizations for those studies with incomparable baseline treatments. Second, the interpretation of correlations between treatments or outcomes with respect to relative effects can be difficult. For example, we cannot directly calculate the correlation between treatments via correlation between differences of treatment effects. Furthermore, our CB model restricts the variance of a baseline effect to always be smaller than that of other treatments. That is, the variance of population mean of baseline treatment, Δ_iBl_, is Var(α_iBl_), whereas for other treatments we have Var(α_iBl_) + Var(δ_iBkl_), which is never smaller than Var(α_iBl_).

As an alternative, we introduce an arm-based (AB) approach10, 21 by respecifying mean structure (2) as

Δ_ikl_= μ_kl_ + v_ikl_, 6

where μ_kl_ is the fixed mean effect of treatment k with respect to outcome l and v_ikl_ is the study-specific random effect. In this approach, we estimate the absolute treatment effect size, μ_kl_, not the relative effect size, d_kl_.

If we begin by assuming independent random effects between outcomes, then the random effects v_ikl_ in (6) can be structured as (v_i1l_,…,v_iKl_)^T^ ∼ MVN ( 0 , Λ_l_^Trt^ ) with Λ_l_^Trt^ a K × K unstructured covariance matrix having relations of random effects between treatments, for l = 1, …, L. We denote this model as ABRE1. Alternatively, we can allow dependence of random effects between outcomes but independence between treatments by defining (v_ik1_, …, v_ikL_)^T^∼ MVN ( 0 , Λ_k_^Out^ ) where Λ_k_^Out^ is a L × L unstructured covariance matrix having relations between outcomes, for k = 1, …, K. We refer to this model as ABRE2. Again, we can also use the same Λ^Out^ for all k when it is reasonable to do so.

The parameters in arm-based models permit more straightforward interpretation, especially in estimating a pure treatment effect. However, these models do require strong assumptions regarding the similarity and exchangeability of all populations, in order to preserve the randomization and permit meaningful clinical inference. Note that in AB models, there is no restriction on variances of random effects because all of our covariance matrices are unstructured. That is, AB models are less constrained, but thus have slightly larger number of parameters than CB models.

## Choice of Priors

Lu and Ades assume a noninformative prior on each parameter, in order to let the data dominate the posterior calculation. For α_iBl_ and d_kl_, a normal distribution with mean 0 and variance 100^2^ is used, and a Uniform (0.01, 10) is assigned for τ in LAREhom. In all CB models, we assume α_iBl_ follows a N ( a_l_ , ξ_l_^2^ ) rather than a N(0, 100^2^) distribution, where a_l_ is the mean reference treatment effect, with noninformative priors for a_l_ and ξ_l_; namely, N(0, 100^2^) and Uniform(0.01, 10), respectively. Throughout all CB and AB models, the fixed effects (d_kl_ and μ_kl_, respectively) follow a N(0, 100^2^) distribution, while the inverse covariance matrices follow a Wishart(Ω, γ) having mean γΩ^−1^, with the matrix dimension usually chosen for the degrees of freedom parameter γ because it is the smallest value that will still yield a proper prior.22 We can select Ω to be γ times a prior guess for the covariance matrix (Ω_0_). Since we do not know the true covariance matrices, we begin with a vague Wishart prior having Ω_0_ = ( 5 … 0 ⋮ ⋱ ⋮ 0 … 5 ) , and later investigate more informative Wishart priors in a sensitivity analysis.

## Decisionmaking

Regarding Bayesian model choice, we adopt the Deviance Information Criterion (DIC).22,23 DIC is a hierarchical models generalization of the Akaike Information Criterion, and is the sum of D̄, a measure of goodness of fit, and P_D_, a measure of complexity. For all CB and AB models we implement, we insist that only the observed data contribute to the calculation of D̄.24

We can identify the best treatments based on a reasonable measurement of the effect size.25 For instance, we can calculate the probability of being the best or second best treatment, which we call the “Best12” probability. Suppose Δ_kl_ is the marginal mean effect of having event l under treatment k, modeled from (2) using the posterior of d_kl_ and posterior mean of μ_i1l_ across studies, instead of δ_iBkl_ and μ_iBl_ in CB models. For AB models, we can obtain Δ_kl_ by plugging in the posterior of μ_kl_ in (6), noting that the prior mean of v_ikl_ is 0. Denoting the data on outcome l by y_l_, then define the “Best12” probability under each outcome as

Pr{k is the best treatment ∣ y_l_} = Pr{rank(Δ_kl_) = 1 or 2 ∣ y_l_} 7

To integrate these univariate probabilities over all the outcomes and obtain one omnibus measure of “best,” we propose an overall, weighted score denoted by S_k_. Suppose all measurements have the same directionality, that is, small values indicate better condition in all outcomes, our overall score is defined as

S_k_ = ∑_l_ w_l_ Δ_kl_, 8

where w_l_ is the weight for outcome l, and ∑_l_w_l_ = 1. This score can be used to obtain overall Best12 probabilities by replacing Δ_kl_ by S_k_ in (7). The weights can be chosen by physicians or public health professionals based on their preferences (say, for weighting safety versus efficacy).

## Simulation Study Settings

In this simulation, we generate 1,000 data pairs (ȳ_ik1_, ȳ_ik2_) and fit the LAREhom, CBRE2, and ABRE2 models to investigate how the missingness in our design affects 5 percent two-sided Type I error, power, and the rates of incorrect decisions when the correlation between outcomes is incorporated into the models (CBRE2 and ABRE2) or not (LAREhom). Figure 2 illustrates the design of the simulated complete and partially missing data. For the “complete” data, we generate artificial data from 40 studies having two treatments and two outcomes featuring moderate positive correlation between outcomes, but independence between arms. In panel (b), we drop 20 studies in the first outcome; that is, we mimic our OA data, in which only half the studies report the disability outcome. For simplicity, we assume that every study has sample size 100 and standard deviation of 2 for every arm.

Figure 2 Data structure for simulation; (a) complete data and (b) partially missing data

Figure 2 shows our simulation settings graphically; (a) complete data and (b) partially missing data. Panel (a) has four vertically long rectangles representing 40 studies. The first two rectangles are for the first outcome and the next two are for the second outcome with two treatments. Panel (b) has the same format as panel (a) but the lengths of first two rectangles are half of the original length representing 20 studies.

To sample the partially missing data, we compare the results under missing completely at random (MCAR), missing at random (MAR), and missing not at random (MNAR) mechanisms. The MCAR mechanism assumes that the missingness does not depend on the data, so we choose 20 studies randomly and make ȳ_i11_ and ȳ_i21_ missing for those studies. The MAR mechanism assumes that the missingness depends only on the observed data, but not on the missing data, whereas MNAR missingness can depend on both observed and unobserved data. To generate partially missing data under the MAR and MNAR mechanisms, we first calculate the ‘probability of missing’ (p_i,mis_) for study i by applying a logit model with the observed or missing data as covariates. Here ȳ_i12_ and ȳ_i22_ are considered as observed data, and ȳ_i11_ and ȳ_i21_ are missing data since they are not fully observed in our design. We use the following two logit models:

MAR: logit(p_i,mis_) = 2 + y¯_i12_ − y¯_i22_ 9

MNAR: logit(p_i,mis_) = − 4 − y¯_i11_ + y¯_i22_. 10

The coefficients are selected to result in a mean p_i,mis_ of about 30 to 40 percent. Given p_i,mis_, we generate the missingness indicator vector until 20 studies are selected as missing data.

For the true parameters, ( μ_11_^*^ , μ_21_^*^ , μ_12_^*^ , μ_22_^*^ ) = ( 0 , 0 , 0 , 3 ) is chosen in (6), yielding d_21_^*^ = 0 and d_22_^*^ = 3 in the LAREhom and CBRE models. We calculate Type I error in terms of parameter d_21_ in the three models, with the superscript * indicating the truth. To estimate power at two particular alternatives, we select ( μ_11_^*^ , μ_21_^*^ , μ_12_^*^ , μ_22_^*^ ) = ( 0 , 1 , 0 , 3 ) and ( 0 , 2 , 0 , 3 ) , giving d_21_^*^ = 1 and 2 , respectively, which we notate as “Power1” and “Power2.” We also calculate the rate of incorrectly selecting the best treatment, given as Pr ( μ_11_^ > μ_21_^ ) under Power1 and 2 scenarios because the truth is that μ_11_^*^ < μ_21_^*^ . This rate should be around 0.5 under the Type I error setting.

For the random effect parameters, in (6), we generate them from ( ν_i 11_^AB^ ν_i 21_^AB^ ) ~ MVN ( ( 0 0 ) , ( 1 ρ_AB_^∗^ ρ_AB_^∗^ 1 ) ) and ( ν_i 12_^AB^ ν_i 22_^AB^ ) ∼ MVN ( ( 0 0 ) , ( 3 3 ρ_AB_^∗^ 3 ρ_AB_^∗^ 3 ) ) , which on the CB scale corresponds to ( ν_i 21_^CB^ ν_i 22_^CB^ ) ∼ MVN ( ( 0 0 ) , ( 2 3 ρ_AB_^∗^ 3 ρ_AB_^∗^ 2 ) ) . Here, the superscripts and subscripts on v_ikl_ and ρ*, AB and CB, indicate the model used. From the covariance matrix of random effects in the CB model, we can easily calculate the true correlation in the CB model, ρ_CB_^∗^ = (3)/(2) ρ_AB_^∗^ . To ensure a positive definite covariance matrix for the random effects in the CB model, ρ_AB_^∗^ should therefore be between − (2)/(3) and (2)/(3) . We set ρ_AB_^∗^ = 0.6 and 0.0 which induces ρ_CB_^∗^ = 0.9 and 0.0 .

For the OA data analysis, WinBUGS is used to generate two parallel chains of 50,000 MCMC samples after a 50,000-sample burn-in. To check MCMC convergence, we used standard diagnostics, including trace plots and lag 1 sample autocorrelations. The WinBUGS codes are now publicly available at www.biostat.umn.edu/~brad/software.html.

We used the R2WinBUGS package26 in R to perform our simulation studies, where we call WinBUGS27 1,000 times from R, once for each simulated data set. In each case, we obtain 20,000 samples, after a 20,000 sample burn-in, and collect medians of parameters across 1,000 simulated datasets, then estimate Type I error and power.