# WinBUGS Codes

#BUGS code for LAREhom

model {

 # Pain
 sw1[1] <- 0
 for (i in 1:N1) {
  mean1[i] <- mu1[s1[i]] + delta1[i]*(1-equals(t1[i],b1[i]))
  y1[i] ∼ dnorm(mean1[i], prec1[i])
  se1[i] <- sd1[i]/sqrt(n1[i])
  prec1[i] <- 1/pow(se1[i],2)
  delta1[i] ∼ dnorm(md1[i], taud1[i])
  taud1[i] <- tau1 * (1+equals(m1[i],3)/3)
  md1[i] <- d1[t1[i]] - d1[b1[i]] + equals(m1[i],3)*sw1[i]

  fitted1[i] <- mean1[i]
  res1[i] <- y1[i] - mean1[i]
  dev1[i] <- (y1[i] - mean1[i])*(y1[i] - mean1[i])*prec1[i]
 }

 resdev1 <- sum(dev1[])

 for (i in 2:N1) { sw1[i] <- (delta1[i-1] - d1[t1[i-1]] +  d1[b1[i-1]])/2 }
 for (j in 1:NS1) { mu1[j] ∼ dnorm(0, 0.0001) }

 d1[1] <- 0
 for (k in 2:NT) { d1[k] ∼ dnorm(0, 0.0001) }

 sig1 ∼ dunif(0.01, 10)
 tau1 <- 1/pow(sig1, 2)

 # Disability
 sw2[1] <- 0
 for (i in 1:N2) {
  mean2[i] <- mu2[s2[i]] + delta2[i]*(1-equals(t2[i],b2[i]))
  y2[i] ∼ dnorm(mean2[i], prec2[i])
  se2[i] <- sd2[i]/sqrt(n2[i])
  prec2[i] <- 1/pow(se2[i],2)
  delta2[i] ∼ dnorm(md2[i], taud2[i])
  taud2[i] <- tau2 * (1+equals(m2[i],3)/3)
  md2[i] <- d2[t2[i]] - d2[b2[i]] + equals(m2[i],3)*sw2[i]

  fitted2[i] <- mean2[i]
  res2[i] <- y2[i] - mean2[i]
  dev2[i] <- (y2[i] - mean2[i])*(y2[i] - mean2[i])*prec2[i]
 }

 resdev2 <- sum(dev2[])

 for (i in 2:N2) { sw2[i] <- (delta2[i-1] - d2[t2[i-1]] + d2[b2[i-1]])/2 }
 for (j in 1:NS2) { mu2[j] ∼ dnorm(0, 0.0001) }

 d2[1] <- 0
 for (k in 2:NT) { d2[k] ∼ dnorm(0, 0.0001) }

 sig2 ∼ dunif(0.01, 10)
 tau2 <- 1/pow(sig2, 2)

 resdev <- resdev1 + resdev2

 # ranking
 for (i in 1:nP1) { mmu1[i] <- mu1[study1[i]] }
 for (i in 1:nP2) { mmu2[i] <- mu2[study2[i]] }
 mP1 <- mean(mmu1[])           # Take average of mu1[]
 SD1 <- sd(mmu1[])
 mP2 <- mean(mmu2[])           # Take average of mu1[]
 SD2 <- sd(mmu2[])

 for (k in 1:NT) {
  T.1[k] <- mP1 + d1[k]
  rk.1[k] <- rank(T.1[], k)
  best1.1[k] <- equals(rk.1[k], 1)
  best2.1[k] <- equals(rk.1[k], 2)
  best12.1[k] <- best1.1[k] + best2.1[k]

  T.2[k] <- mP2 + d2[k]
  rk.2[k] <- rank(T.2[], k)
  best1.2[k] <- equals(rk.2[k], 1)
  best2.2[k] <- equals(rk.2[k], 2)
  best12.2[k] <- best1.2[k] + best2.2[k]

  T.eq[k] <- 0.5*T.1[k] + 0.5*T.2[k]
  rk.eq[k] <- rank(T.eq[], k)
  best1.eq[k] <- equals(rk.eq[k], 1)
  best2.eq[k] <- equals(rk.eq[k], 2)
  best12.eq[k] <- best1.eq[k] + best2.eq[k]

  T.pain[k] <- 0.8*T.1[k] + 0.2*T.2[k]
  rk.pain[k] <- rank(T.pain[], k)
  best1.pain[k] <- equals(rk.pain[k], 1)
  best2.pain[k] <- equals(rk.pain[k], 2)
  best12.pain[k] <- best1.pain[k] + best2.pain[k]

  T.dis[k] <- 0.2*T.1[k] + 0.8*T.2[k]
  rk.dis[k] <- rank(T.dis[], k)
  best1.dis[k] <- equals(rk.dis[k], 1)
  best2.dis[k] <- equals(rk.dis[k], 2)
  best12.dis[k] <- best1.dis[k] + best2.dis[k]
 }
}

# Data

list(N1=111, NS1=51, N2=57, NS2=26, NT=11,
    study1 = c(1,2,5,7,10, 12,14,15,16,21, 28,31,32,35,36, 40,42,43,44,45,
               46,47,48,49,51), nP1=25,
    study2 = c(1,2,5,7,10, 12,14,15,16,21, 24), nP2=11)

# Data - pain

s1[]   t1[]   y1[]   sd1[]  n1[]   b1[]   m1[]
1      1      7.700  2.300  17     1      1
1      7      0.700  1.000  17     1      2
2      1      4.770  2.120  50     1      1
2      7      3.770  1.730  52     1      2
3      2      2.800  1.220  149    2      1
3      7      2.280  1.200  144    2      2
3      9      2.420  1.440  146    2      3
4      2      5.500  2.070  50     2      1
4      7      4.590  2.400  52     2      2
5      1      4.873  2.063  124    1      1
5      8      4.607  2.457  125    1      2
6      2      3.780  2.345  23     2      1
6      9      2.560  1.962  23     2      2
7      1      5.070  2.530  193    1      1
7      9      4.060  2.530  199    1      2
8      3      6.300  1.900  10     3      1
8      4      5.000  3.200  10     3      2
8      5      5.500  2.700  10     3      3
9      3      4.440  3.510  33     3      1
9      4      4.730  3.480  38     3      2
9      5      4.030  3.300  32     3      3
10     1      4.250  2.367  94     1      1
10     7      3.858  2.201  88     1      2
11     2      3.750  2.500  23     2      1
11     8      3.650  0.350  22     2      2
12     1      3.370  1.780  19     1      1
12     10     2.410  2.050  22     1      2
13     3      4.180  1.659  19     3      1
13     6      3.740  2.360  39     3      2
14     1      2.959  2.394  70     1      1
14     9      2.255  2.068  72     1      2
15     1      2.380  1.403  27     1      1
15     8      1.810  1.403  27     1      2
15     9      1.560  1.400  25     1      3
16     1      3.459  2.355  50     1      1
16     7      3.523  2.193  45     1      2
17     3      4.000  2.600  33     3      1
17     11     3.900  2.000  34     3      2
18     3      3.178  1.784  20     3      1
18     6      2.834  2.136  20     3      2
19     2      3.940  2.220  68     2      1
19     7      3.090  1.540  69     2      2
20     9      1.800  1.600  24     9      1
20     10     1.300  1.200  24     9      2
21     1      1.686  1.057  15     1      1
21     10     1.314  1.143  29     1      2
22     3      6.670  1.780  30     3      1
22     11     5.250  1.900  30     3      2
23     3      6.900  2.000  23     3      1
23     4      3.800  2.200  32     3      2
23     5      4.600  2.500  31     3      3
24     2      2.560  1.800  36     2      1
24     7      2.300  1.954  33     2      2
25     3      3.500  2.900  20     3      1
25     6      2.200  2.800  20     3      2
26     3      6.750  2.375  10     3      1
26     6      5.250  1.425  10     3      2
27     1      3.300  1.500  34     1      1
27     9      3.000  1.500  34     1      2
28     2      2.080  2.090  17     2      1
28     7      2.190  1.670  17     2      2
29     7      3.800  1.600  23     7      1
29     8      2.400  1.600  23     7      2
30     1      4.000  0.743  6      1      1
30     9      1.471  0.643  9      1      2
31     1      5.385  1.528  35     1      1
31     9      5.190  1.657  32     1      2
32     2      1.397  1.242  21     2      1
32     7      1.660  1.463  19     2      2
33     2      1.426  1.026  18     2      1
33     6      2.094  1.712  20     2      2
34     1      3.095  2.030  78     1      1
34     2      2.550  1.945  82     1      2
34     7      3.110  2.010  80     1      3
35     1      4.030  2.080  18     1      1
35     2      4.000  1.560  18     1      2
35     7      3.190  1.850  16     1      3
36     2      5.990  2.400  18     2      1
36     6      5.180  2.110  20     2      2
37     3      4.100  2.600  10     3      1
37     6      0.700  0.700  12     3      2
38     6      0.600  0.100  25     6      1
38     9      1.040  0.270  25     6      2
39     1      4.180  1.950  108    1      1
39     7      3.755  2.400  109    1      2
40     7      3.840  2.750  32     7      1
40     8      3.700  1.810  32     7      2
41     1      3.550  1.700  34     1      1
41     9      2.400  1.750  34     1      2
42     1      4.930  2.020  8      1      1
42     6      5.350  0.970  8      1      2
43     1      2.764  2.252  14     1      1
43     7      1.422  2.202  14     1      2
44     1      1.320  0.760  30     1      1
44     10     1.280  0.740  30     1      2
45     1      3.360  1.540  28     1      1
45     9      2.280  1.690  27     1      2
46     1      2.096  1.844  12     1      1
46     6      1.165  1.671  11     1      2
47     1      3.650  1.700  36     1      1
47     9      2.100  1.500  36     1      2
47     10     2.150  1.150  36     1      3
48     1      4.400  1.400  66     1      1
48     9      3.600  0.700  66     1      2
48     10     2.700  1.900  66     1      3
49     2      7.200  6.630  98     2      1
49     7      6.710  6.880  100    2      2
50     1      3.250  1.650  44     1      1
50     9      2.450  1.650  45     1      2
51     2      4.556  0.467  36     2      1
51     9      3.667  0.422  37     2      2
END

#Data - disability

s2[]   t2[]   y2[]   sd2[]  n2[]   b2[]   m2[]
1      1      6.360  0.790  17     1      1
1      7      1.280  0.970  17     1      2
2      1      5.960  2.320  50     1      1
2      7      3.740  2.690  52     1      2
3      2      2.250  1.225  149    2      1
3      7      1.800  1.200  144    2      2
3      9      1.850  1.225  146    2      3
4      2      6.180  2.750  50     2      1
4      7      6.070  2.950  52     2      2
5      1      3.757  2.237  124    1      1
5      8      3.110  1.833  125    1      2
6      2      3.920  2.936  23     2      1
6      9      3.660  2.869  23     2      2
7      1      3.045  1.720  193    1      1
7      9      2.695  1.805  199    1      2
8      3      5.100  1.700  10     3      1
8      4      5.500  3.000  10     3      2
8      5      5.100  2.300  10     3      3
9      3      4.630  3.540  33     3      1
9      4      4.930  3.630  38     3      2
9      5      4.400  3.440  32     3      3
10     1      1.850  1.374  94     1      1
10     7      1.958  1.539  88     1      2
11     2      5.980  1.940  23     2      1
11     8      6.600  2.150  22     2      2
12     1      2.990  1.630  19     1      1
12     10     2.806   2.327  22    1      2
13     3      4.590  1.681  19     3      1
13     6      3.960  2.425  39     3      2
14     1      3.660  1.636  70     1      1
14     9      2.881  1.633  72     1      2
15     1      3.860  1.351  27     1      1
15     8      3.700  1.351  27     1      2
15     9      3.610  1.350  25     1      3
16     1      0.357  0.280  50     1      1
16     7      0.428  0.368  45     1      2
17     3      4.010  1.583  33     3      1
17     11     3.469  1.615  34     3      2
18     3      3.420  1.654  20     3      1
18     6      2.933  2.034  20     3      2
19     2      1.930  1.880  68     2      1
19     7      1.850  2.260  69     2      2
20     9      1.800  1.300  24     9      1
20     10     1.200  1.000  24     9      2
21     1      4.490  1.750  15     1      1
21     10     3.560  2.090  29     1      2
22     3      4.618  1.331  30     3      1
22     11     4.525  1.717  30     3      2
23     3      4.850  1.750  23     3      1
23     4      3.850  2.030  32     3      2
23     5      3.680  1.650  31     3      3
24     1      2.500  0.850  10     1      1
24     9      2.300  0.840  10     1      2
25     3      3.893  2.723  41     3      1
25     7      1.927  1.826  42     3      2
26     2      6.559  0.899  78     2      1
26     7      6.286  1.038  80     2      2
END


# Inits1

list(mu1 = c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0,
              0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0),
    d1 = c(NA,0,0,0,0, 0,0,0,0,0, 0), sig1 = 1,
    mu2 = c(0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0,0,0,0,0, 0),
    d2 = c(NA,0,0,0,0, 0,0,0,0,0, 0), sig2=1)

# Inits2

list(mu1 = c(1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1,
		  1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1),
    d1 = c(NA,1,1,1,1, 1,1,1,1,1, 1), sig1 = 0.5,
    mu2 = c(1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1,1,1,1,1, 1),
    d2 = c(NA,1,1,1,1, 1,1,1,1,1, 1), sig2=0.5)


#BUGS code for CBREhom

model {

 for (j in 1:NS) {
  for (h in 1:NO) {
   delta[j, 1, h] <- 0
  }
 }

 for (i in 1:N) {
  mean[i] <- mu[s[i],l[i]] + delta[s[i], t[i], l[i]]
  y[i] ∼ dnorm(mean[i], prec[i])
  se[i] <- sd[i]/sqrt(n[i])
  prec[i] <- 1/pow(se[i],2)
  fitted[i] <- mean[i]
  res[i] <- y[i] - mean[i]
  dev[i] <- (y[i] - mean[i])*(y[i] - mean[i])*prec[i]
 }

 for (j in 1:NS) {
  for (k in 2:NT) {
   delta[j, k, 1:NO] ∼ dmnorm(d[k-1, 1:NO], invR[1:NO, 1:NO])
  }
 }

 for (j in 1:NS) {
  for (h in 1:NO) {
   mu[j,h] ∼ dnorm(mP[h], tauP[h])
  }
 }

 for (h in 1:NO) {
  mP[h] ∼ dnorm(0, 0.0001)
  tauP[h] <- 1/pow(sdP[h], 2)
  sdP[h] ∼ dunif(0.01, 10)
 }

 for (k in 1:(NT-1)) { d[k, 1:NO] ∼ dmnorm(md[1:NO], invcovd[1:NO, 1:NO]) }
 invR[1:NO, 1:NO] ∼ dwish(Omega[1:NO, 1:NO], 2)
 R[1:NO, 1:NO] <- inverse(invR[ , ])

 sig1 <- sqrt(R[1,1])
 sig2 <- sqrt(R[2,2])
 rho <- R[1,2]/sqrt(R[1,1]*R[2,2])

 sumdev <- sum(dev[])

 # ranking
 dd1[1] <- 0
 dd2[1] <- 0
 for (k in 2:NT) {
  dd1[k] <- d[k-1,1]
  dd2[k] <- d[k-1, 2]
 }

 for (k in 1:NT) {
  T.1[k] <- mP[1] + dd1[k]
  rk.1[k] <- rank(T.1[], k)
  best1.1[k] <- equals(rk.1[k], 1)
  best2.1[k] <- equals(rk.1[k], 2)
  best12.1[k] <- best1.1[k] + best2.1[k]

  T.2[k] <- mP[2] + dd2[k]
  rk.2[k] <- rank(T.2[], k)
  best1.2[k] <- equals(rk.2[k], 1)
  best2.2[k] <- equals(rk.2[k], 2)
  best12.2[k] <- best1.2[k] + best2.2[k]

  T.eq[k] <- 0.5*T.1[k] + 0.5*T.2[k]
  rk.eq[k] <- rank(T.eq[], k)
  best1.eq[k] <- equals(rk.eq[k], 1)
  best2.eq[k] <- equals(rk.eq[k], 2)
  best12.eq[k] <- best1.eq[k] + best2.eq[k]

  T.pain[k] <- 0.8*T.1[k] + 0.2*T.2[k]
  rk.pain[k] <- rank(T.pain[], k)
  best1.pain[k] <- equals(rk.pain[k], 1)
  best2.pain[k] <- equals(rk.pain[k], 2)
  best12.pain[k] <- best1.pain[k] + best2.pain[k]

  T.dis[k] <- 0.2*T.1[k] + 0.8*T.2[k]
  rk.dis[k] <- rank(T.dis[], k)
  best1.dis[k] <- equals(rk.dis[k], 1)
  best2.dis[k] <- equals(rk.dis[k], 2)
  best12.dis[k] <- best1.dis[k] + best2.dis[k]
 }
}


#Data

list(N=168, NT=11, NS=54, NO=2,
md=c(0,0),
invcovd = structure(.Data = c(0.0001,0,
				        0,0.0001), .Dim = c(2, 2)),
Omega = structure(.Data = c(10,0,0,10), .Dim = c(2, 2))
)

s[]   t[]   y[]   sd[]  n[]   l[]
1     1     7.700 2.300 17    1
1     7     0.700 1.000 17    1
1     1     6.360 0.790 17    2
1     7     1.280 0.970 17    2
2     1     4.770 2.120 50    1
2     7     3.770 1.730 52    1
2     1     5.960 2.320 50    2
2     7     3.740 2.690 52    2
3     2     2.800 1.220 149   1
3     7     2.280 1.200 144   1
3     9     2.420 1.440 146   1
3     2     2.250 1.225 149   2
3     7     1.800 1.200 144   2
3     9     1.850 1.225 146   2
4     2     5.500 2.070 50    1
4     7     4.590 2.400 52    1
4     2     6.180 2.750 50    2
4     7     6.070 2.950 52    2
5     1     4.873 2.063 124   1
5     8     4.607 2.457 125   1
5     1     3.757 2.237 124   2
5     8     3.110 1.833 125   2
6     2     3.780 2.345 23    1
6     9     2.560 1.962 23    1
6     2     3.920 2.936 23    2
6     9     3.660 2.869 23    2
7     1     5.070 2.530 193   1
7     9     4.060 2.530 199   1
7     1     3.045 1.720 193   2
7     9     2.695 1.805 199   2
8     3     6.300 1.900 10    1
8     4     5.000 3.200 10    1
8     5     5.500 2.700 10    1
8     3     5.100 1.700 10    2
8     4     5.500 3.000 10    2
8     5     5.100 2.300 10    2
9     3     4.440 3.510 33    1
9     4     4.730 3.480 38    1
9     5     4.030 3.300 32    1
9     3     4.630 3.540 33    2
9     4     4.930 3.630 38    2
9     5     4.400 3.440 32    2
10    1     4.250 2.367 94    1
10    7     3.858 2.201 88    1
10    1     1.850 1.374 94    2
10    7     1.958 1.539 88    2
11    2     3.750 2.500 23    1
11    8     3.650 0.350 22    1
11    2     5.980 1.940 23    2
11    8     6.600 2.150 22    2
12    1     3.370 1.780 19    1
12    10    2.410 2.050 22    1
12    1     2.990 1.630 19    2
12    10    2.806 2.327 22    2
13    3     4.180 1.659 19    1
13    6     3.740 2.360 39    1
13    3     4.590 1.681 19    2
13    6     3.960 2.425 39    2
14    1     2.959 2.394 70    1
14    9     2.255 2.068 72    1
14    1     3.660 1.636 70    2
14    9     2.881 1.633 72    2
15    1     2.380 1.403 27    1
15    8     1.810 1.403 27    1
15    9     1.560 1.400 25    1
15    1     3.860 1.351 27    2
15    8     3.700 1.351 27    2
15    9     3.610 1.350 25    2
16    1     3.459 2.355 50    1
16    7     3.523 2.193 45    1
16    1     0.357 0.280 50    2
16    7     0.428 0.368 45    2
17    3     4.000 2.600 33    1
17    11    3.900 2.000 34    1
17    3     4.010 1.583 33    2
17    11    3.469 1.615 34    2
18    3     3.178 1.784 20    1
18    6     2.834 2.136 20    1
18    3     3.420 1.654 20    2
18    6     2.933 2.034 20    2
19    2     3.940 2.220 68    1
19    7     3.090 1.540 69    1
19    2     1.930 1.880 68    2
19    7     1.850 2.260 69    2
20    9     1.800 1.600 24    1
20    10    1.300 1.200 24    1
20    9     1.800 1.300 24    2
20    10    1.200 1.000 24    2
21    1     1.686 1.057 15    1
21    10    1.314 1.143 29    1
21    1     4.490 1.750 15    2
21    10    3.560 2.090 29    2
22    3     6.670 1.780 30    1
22    11    5.250 1.900 30    1
22    3     4.618 1.331 30    2
22    11    4.525 1.717 30    2
23    3     6.900 2.000 23    1
23    4     3.800 2.200 32    1
23    5     4.600 2.500 31    1
23    3     4.850 1.750 23    2
23    4     3.850 2.030 32    2
23    5     3.680 1.650 31    2
24    2     2.560 1.800 36    1
24    7     2.300 1.954 33    1
25    3     3.500 2.900 20    1
25    6     2.200 2.800 20    1
26    3     6.750 2.375 10    1
26    6     5.250 1.425 10    1
27    1     3.300 1.500 34    1
27    9     3.000 1.500 34    1
28    2     2.080 2.090 17    1
28    7     2.190 1.670 17    1
29    7     3.800 1.600 23    1
29    8     2.400 1.600 23    1
30    1     4.000 0.743 6     1
30    9     1.471 0.643 9     1
31    1     5.385 1.528 35    1
31    9     5.190 1.657 32    1
32    2     1.397 1.242 21    1
32    7     1.660 1.463 19    1
33    2     1.426 1.026 18    1
33    6     2.094 1.712 20    1
34    1     3.095 2.030 78    1
34    2     2.550 1.945 82    1
34    7     3.110 2.010 80    1
35    1     4.030 2.080 18    1
35    2     4.000 1.560 18    1
35    7     3.190 1.850 16    1
36    2     5.990 2.400 18    1
36    6     5.180 2.110 20    1
37    3     4.100 2.600 10    1
37    6     0.700 0.700 12    1
38    6     0.600 0.100 25    1
38    9     1.040 0.270 25    1
39    1     4.180 1.950 108   1
39    7     3.755 2.400 109   1
40    7     3.840 2.750 32    1
40    8     3.700 1.810 32    1
41    1     3.550 1.700 34    1
41    9     2.400 1.750 34    1
42    1     4.930 2.020 8     1
42    6     5.350 0.970 8     1
43    1     2.764 2.252 14    1
43    7     1.422 2.202 14    1
44    1     1.320 0.760 30    1
44    10    1.280 0.740 30    1
45    1     3.360 1.540 28    1
45    9     2.280 1.690 27    1
46    1     2.096 1.844 12    1
46    6     1.165 1.671 11    1
47    1     3.650 1.700 36    1
47    9     2.100 1.500 36    1
47    10    2.150 1.150 36    1
48    1     4.400 1.400 66    1
48    9     3.600 0.700 66    1
48    10     2.700 1.900 66   1
49    2     7.200 6.630 98    1
49    7     6.710 6.880 100   1
50    1     3.250 1.650 44    1
50    9     2.450 1.650 45    1
51    2     4.556 0.467 36    1
51    9     3.667 0.422 37    1
52    1     2.500 0.850 10    2
52    9     2.300 0.840 10    2
53    3     3.893 2.723 41    2
53    7     1.927 1.826 42    2
54    2     6.559 0.899 78    2
54    7     6.286 1.038 80    2
END


#Inits1

list(
d=structure(.Data = c(0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0), .Dim=c(10,2)),
mP = c(0,0), sdP = c(1,1),
invR=structure(.Data=c(1,0,0,1), .Dim=c(2,2)),
mu=structure(.Data=c(0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0,
                      0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0,
                      0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0,
                      0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0,
                      0,0,0,0,0,0,0,0,0,0, 0,0,0,0,0,0,0,0,0,0,
                      0,0,0,0,0,0,0,0), .Dim=c(54,2))
)

#Inits2

list(
d=structure(.Data = c(1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1), .Dim=c(10,2)),
mP = c(1,1), sdP = c(0.5,0.5),
invR=structure(.Data=c(2,0,0,2), .Dim=c(2,2)),
mu=structure(.Data=c(1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1,
                      1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1,
                      1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1,
                      1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1,
                      1,1,1,1,1,1,1,1,1,1, 1,1,1,1,1,1,1,1,1,1,
                      1,1,1,1,1,1,1,1), .Dim=c(54,2))
)

#BUGS code for ABREhom

model {

 for (i in 1:N) {
  y[i] ∼ dnorm(mean[s[i],t[i],l[i]], prec[i])
  prec[i] <- n[i]/pow(sd[i], 2)
  mean[s[i],t[i],l[i]] <- mu[t[i], l[i]] + v[s[i], t[i], l[i]]
  dev[i] <- (y[i]-mean[s[i],t[i],l[i]])*(y[i]-mean[s[i],t[i],l[i]])*prec[i]
  res[i] <- y[i] - mean[s[i],t[i],l[i]]
  fitted[i] <- mean[s[i],t[i],l[i]]
 }
 resdev <- sum(dev[])

 for (j in 1:NS) {
  for (k in 1:NT) {
    v[j, k, 1:NO] ∼ dmnorm(meano[1:NO], invRo[1:NO,1:NO])
  }
 }


 invRo[1:NO,1:NO] ∼ dwish(Omegao[1:NO, 1:NO], NO)
 Ro[1:NO, 1:NO] <- inverse(invRo[ , ])

 corro <- Ro[1,2]/sqrt(Ro[1,1]*Ro[2,2])
 for (h in 1:NO) { sig[h] <- sqrt(Ro[h,h]) }

 for (k in 1:NT) {
  for (h in 1:NO) {
   mu[k,h] ∼ dnorm(0, 0.0001)
  }
 }

 # To compare with CB models
 for (h in 1:NO) {
  for (k in 1:NT) {
   d[k,h] <- mu[k,h] - mu[1,h]
  }
 }

 #rank
 for (k in 1:NT) {
  T.1[k] <- mu[k,1]
  rk.1[k] <- rank(T.1[], k)
  best1.1[k] <- equals(rk.1[k],1)
  best2.1[k] <- equals(rk.1[k],2)
  best12.1[k] <- best1.1[k] + best2.1[k]

  T.2[k] <- mu[k,2]
  rk.2[k] <- rank(T.2[], k)
  best1.2[k] <- equals(rk.2[k],1)
  best2.2[k] <- equals(rk.2[k],2)
  best12.2[k] <- best1.2[k] + best2.2[k]

  T.eq[k] <- 0.5*T.1[k] + 0.5*T.2[k]
  rk.eq[k] <- rank(T.eq[], k)
  best1.eq[k] <- equals(rk.eq[k],1)
  best2.eq[k] <- equals(rk.eq[k], 2)
  best12.eq[k] <- best1.eq[k] + best2.eq[k]

  T.pain[k] <- 0.8*T.1[k] + 0.2*T.2[k]
  rk.pain[k] <- rank(T.pain[], k)
  best1.pain[k] <- equals(rk.pain[k], 1)
  best2.pain[k] <- equals(rk.pain[k], 2)
  best12.pain[k] <- best1.pain[k] + best2.pain[k]

  T.dis[k] <- 0.2*T.1[k] + 0.8*T.2[k]
  rk.dis[k] <- rank(T.dis[], k)
  best1.dis[k] <- equals(rk.dis[k], 1)
  best2.dis[k] <- equals(rk.dis[k], 2)
  best12.dis[k] <- best1.dis[k] + best2.dis[k]
 }
}

#Data

list(
N=168, NT=11, NS=54, NO=2,
meano= c(0,0),
Omegao = structure(.Data = c(10,0,0,10), .Dim = c(2,2))
)

s[]   t[]   y[]   sd[]  n[]   l[]
1     1     7.700 2.300 17    1
1     7     0.700 1.000 17    1
1     1     6.360 0.790 17    2
1     7     1.280 0.970 17    2
2     1     4.770 2.120 50    1
2     7     3.770 1.730 52    1
2     1     5.960 2.320 50    2
2     7     3.740 2.690 52    2
3     2     2.800 1.220 149   1
3     7     2.280 1.200 144   1
3     9     2.420 1.440 146   1
3     2     2.250 1.225 149   2
3     7     1.800 1.200 144   2
3     9     1.850 1.225 146   2
4     2     5.500 2.070 50    1
4     7     4.590 2.400 52    1
4     2     6.180 2.750 50    2
4     7     6.070 2.950 52    2
5     1     4.873 2.063 124   1
5     8     4.607 2.457 125   1
5     1     3.757 2.237 124   2
5     8     3.110 1.833 125   2
6     2     3.780 2.345 23    1
6     9     2.560 1.962 23    1
6     2     3.920 2.936 23    2
6     9     3.660 2.869 23    2
7     1     5.070 2.530 193   1
7     9     4.060 2.530 199   1
7     1     3.045 1.720 193   2
7     9     2.695 1.805 199   2
8     3     6.300 1.900 10    1
8     4     5.000 3.200 10    1
8     5     5.500 2.700 10    1
8     3     5.100 1.700 10    2
8     4     5.500 3.000 10    2
8     5     5.100 2.300 10    2
9     3     4.440 3.510 33    1
9     4     4.730 3.480 38    1
9     5     4.030 3.300 32    1
9     3     4.630 3.540 33    2
9     4     4.930 3.630 38    2
9     5     4.400 3.440 32    2
10    1     4.250 2.367 94    1
10    7     3.858 2.201 88    1
10    1     1.850 1.374 94    2
10    7     1.958 1.539 88    2
11    2     3.750 2.500 23    1
11    8     3.650 0.350 22    1
11    2     5.980 1.940 23    2
11    8     6.600 2.150 22    2
12    1     3.370 1.780 19    1
12    10    2.410 2.050 22    1
12    1     2.990 1.630 19    2
12    10    2.806 2.327 22    2
13    3     4.180 1.659 19    1
13    6     3.740 2.360 39    1
13    3     4.590 1.681 19    2
13    6     3.960 2.425 39    2
14    1     2.959 2.394 70    1
14    9     2.255 2.068 72    1
14    1     3.660 1.636 70    2
14    9     2.881 1.633 72    2
15    1     2.380 1.403 27    1
15    8     1.810 1.403 27    1
15    9     1.560 1.400 25    1
15    1     3.860 1.351 27    2
15    8     3.700 1.351 27    2
15    9     3.610 1.350 25    2
16    1     3.459 2.355 50    1
16    7     3.523 2.193 45    1
16    1     0.357 0.280 50    2
16    7     0.428 0.368 45    2
17    3     4.000 2.600 33    1
17    11    3.900 2.000 34    1
17    3     4.010 1.583 33    2
17    11    3.469 1.615 34    2
18    3     3.178 1.784 20    1
18    6     2.834 2.136 20    1
18    3     3.420 1.654 20    2
18    6     2.933 2.034 20    2
19    2     3.940 2.220 68    1
19    7     3.090 1.540 69    1
19    2     1.930 1.880 68    2
19    7     1.850 2.260 69    2
20    9     1.800 1.600 24    1
20    10    1.300 1.200 24    1
20    9     1.800 1.300 24    2
20    10    1.200 1.000 24    2
21    1     1.686 1.057 15    1
21    10    1.314 1.143 29    1
21    1     4.490 1.750 15    2
21    10    3.560 2.090 29    2
22    3     6.670 1.780 30    1
22    11    5.250 1.900 30    1
22    3     4.618 1.331 30    2
22    11    4.525 1.717 30    2
23    3     6.900 2.000 23    1
23    4     3.800 2.200 32    1
23    5     4.600 2.500 31    1
23    3     4.850 1.750 23    2
23    4     3.850 2.030 32    2
23    5     3.680 1.650 31    2
24    2     2.560 1.800 36    1
24    7     2.300 1.954 33    1
25    3     3.500 2.900 20    1
25    6     2.200 2.800 20    1
26    3     6.750 2.375 10    1
26    6     5.250 1.425 10    1
27    1     3.300 1.500 34    1
27    9     3.000 1.500 34    1
28    2     2.080 2.090 17    1
28    7     2.190 1.670 17    1
29    7     3.800 1.600 23    1
29    8     2.400 1.600 23    1
30    1     4.000 0.743 6     1
30    9     1.471 0.643 9     1
31    1     5.385 1.528 35    1
31    9     5.190 1.657 32    1
32    2     1.397 1.242 21    1
32    7     1.660 1.463 19    1
33    2     1.426 1.026 18    1
33    6     2.094 1.712 20    1
34    1     3.095 2.030 78    1
34    2     2.550 1.945 82    1
34    7     3.110 2.010 80    1
35    1     4.030 2.080 18    1
35    2     4.000 1.560 18    1
35    7     3.190 1.850 16    1
36    2     5.990 2.400 18    1
36    6     5.180 2.110 20    1
37    3     4.100 2.600 10    1
37    6     0.700 0.700 12    1
38    6     0.600 0.100 25    1
38    9     1.040 0.270 25    1
39    1     4.180 1.950 108   1
39    7     3.755 2.400 109   1
40    7     3.840 2.750 32    1
40    8     3.700 1.810 32    1
41    1     3.550 1.700 34    1
41    9     2.400 1.750 34    1
42    1     4.930 2.020 8     1
42    6     5.350 0.970 8     1
43    1     2.764 2.252 14    1
43    7     1.422 2.202 14    1
44    1     1.320 0.760 30    1
44    10    1.280 0.740 30    1
45    1     3.360 1.540 28    1
45    9     2.280 1.690 27    1
46    1     2.096 1.844 12    1
46    6     1.165 1.671 11    1
47    1     3.650 1.700 36    1
47    9     2.100 1.500 36    1
47    10    2.150 1.150 36    1
48    1     4.400 1.400 66    1
48    9     3.600 0.700 66    1
48    10    2.700 1.900 66    1
49    2     7.200 6.630 98    1
49    7     6.710 6.880 100   1
50    1     3.250 1.650 44    1
50    9     2.450 1.650 45    1
51    2     4.556 0.467 36    1
51    9     3.667 0.422 37    1
52    1     2.500 0.850 10    2
52    9     2.300 0.840 10    2
53    3     3.893 2.723 41    2
53    7     1.927 1.826 42    2
54    2     6.559 0.899 78    2
54    7     6.286 1.038 80    2
END

#Inits1

list(
mu = structure(.Data = c(0,0,0,0,0, 0,0,0,0,0, 0, 0,0,0,0,0, 0,0,0,0,0, 0), .Dim=c(11,2)),
invRo = structure(.Data=c(1,0,0,1), .Dim=c(2,2))
)

#Inits2

list(
mu = structure(.Data = c(1,1,1,1,1, 1,1,1,1,1, 1, 1,1,1,1,1, 1,1,1,1,1, 1), .Dim=c(11,2)),
invRo = structure(.Data=c(2,0,0,2), .Dim=c(2,2))
)