# Abbreviations

AB: Arm based
ABRE: Arm-based random effects
AIMS: Arthritis Impact Measurement Scale
CB: Contrast based
CBRE: Contrast-based random effects
DIC: Deviance Information Criterion
EPC: Evidence-based Practice Center
HAQ: Health Assessment Questionnaire
KOOS: Knee Injury and Osteoarthritis Outcome Score
LA: Lu and Ades
LAFE: LA-fixed effects
LAREhom: Lu and Ades-style homogeneous random effects
MAR: Missing at random
MCAR: Missing completely at random
MCMC: Markov chain Monte Carlo
MNAR: Missing not at random
MOS: Medical Outcome Study
MSE: Mean squared error
MTC: Mixed treatment comparison
OA: Osteoarthritis
RCT: Randomized controlled trial
SD: Standard deviation
SF-36 physical function: 36-Item Short-Form Health Survey
SMD: Standardized mean differences
VAS: Visual Analogue Scale
WOMAC: Western Ontario MacMaster