# Results

Of the 66 authors, we were able to contact 45 (68 percent). Of those 45 authors, 28 (62 percent) provided additional data for 29 studies, including 4 who provided datasets. Among authors whom we were able to contact, reasons for not sending data included: no current access to the data and need for additional time to find and format the data (e.g., data stored on a floppy disk).

All authors who provided data did so by the third request for information (second reminder). We received information on 10 studies after only one request (34 percent). Two requests were required for 13 studies (45 percent), and three were required for 6 studies (21 percent). We received no additional information after three requests and received no additional data in response to telephone contact.

There was no difference in the likelihood of providing data between authors of studies in which 2 × 2 tables could not be calculated compared with authors of studies with discrepancies (40 percent vs. 54 percent, p=0.36). Of the 17 studies in which there was a discrepancy between reported results for diagnostic accuracy and constructed 2 × 2 tables, 7 of 13 authors (54 percent) provided data on 7 studies (41 percent),7, 11, 14, 16, 18, 23, 26 including one dataset.16 We were unable to contact four authors,10, 12, 17, 19 one author forwarded our request to a colleague who did not provide the data20-22, one provided data for one of two studies,15 and one declined telephone contact.13 Of the 60 studies missing information to generate 2 × 2 tables, 21 of 53 authors (40 percent) provided additional or confirmatory data on 22 studies (37 percent),9, 24, 25, 27-32, 46-59 including three datasets.27, 30, 56 Reasons for not providing data were similar to those for authors of studies with discrepancies. We were unable to locate 10 authors,33, 34, 39, 60-67 1 author opted not to send the data,40, 41 2 did not have access to the data,38, 68 5 forwarded our request to a colleague who did not provide the data42, 69 or requested that we contact another author who did not provide the data,70-72 1 was too busy to comply,43 1 author had died,73 a language barrier prevented meaningful telephone contact with 5 authors,66, 74-77 and data from 8 were still pending at the time this report was written.58, 78-85

Authors of more recent studies were more likely to be located and provide data (p=0.02). The mean year of publication of studies for which we received additional data was 2010. The mean year of publication of studies by contacted authors who did not provide additional data was 2008, while the average publication year for authors of studies we could not locate was 2007. Country of publication did not appear to predict the likelihood of receiving data. We received data from authors based in Belgium (1 study), Brazil (1 study), Egypt (2 studies), France (6 studies), Germany (1 study), Israel (1 study), Italy (3 studies), Japan (1 study), Korea (2 studies), Luxembourg (1 study), the Netherlands (1 study), Romania (3 studies), Taiwan (1 study), Turkey (1 study) and the United States (4 studies).

## Effects on Diagnostic Accuracy

For diagnosing fibrosis, additional data was provided for 12 blood tests, 5 of which were evaluated at two different cutoffs (Table 1). The number of additional studies for specific tests and cutoffs ranged from zero to nine (zero additional studies occurred when additional data were obtained, but only for studies with discrepancies, so that one set of data was replaced by another). For the Fibrotest at a cutoff of >0.70 or >0.80, the number of studies increased from 5 to 10, but there was little impact on the positive likelihood ratio (5.5 to 7.6) or the negative likelihood ratio (0.81 to 0.65). For the APRI at a cutoff of >0.5 to >0.55, the number of available studies increased from 28 to 38 (40 samples), with little impact on median estimates. The number of additional studies ranged from zero to four for other blood tests. The largest impact on positive likelihood ratios was observed for the FIB-4 at a cutoff of >3.25, with the median increasing from 2.4 to 9.3, resulting in reclassification from less useful to moderately useful. For the negative likelihood ratio, the largest impact occurred with the FibroIndex at a cutoff of >1.25, with the median increasing from 0.15 to 0.62, resulting in reclassification from moderately useful to less useful. Although re-analysis with additional data also resulted in reclassification of the positive likelihood ratio for the age-platelet index at a cutoff of >6.0 and the negative likelihood ratio for the Fibrotest at a cutoff of >0.10 to >0.22, the actual change in the median estimates was small to minimal (5.1 to 4.5 and 0.21 to 0.17, respectively). For the Lok Index, no studies reported accuracy for diagnosis of fibrosis in the original report. Based on additional data from three studies, the median positive likelihood ratio was 2.9 (range 2.0 to 3.1) and the median negative likelihood ratio 0.53 (range 0.31 to 0.65).

Table 1 Diagnostic accuracy of tests for fibrosis^a^

Fibrosis Test (cutoff) | Number of Samples | Sensitivity (median, range) | Specificity (median, range) | Positive Likelihood Ratio (median, range) | Negative Likelihood Ratio (median, range)
Platelets <140 to <163 | 8 | 0.56 (0.28-0.89) | 0.91 (0.69-1.0) | 6.3 (2.3-14) | 0.48 (0.16-0.78)
With additional data | 10^b^ | 0.57 (0.28-0.89) | 0.91 (0.58-1.0) | 6.3 (1.64-35) | 0.48 (0.16-0.78)
API >3.5 ≥4.0 | 5 | 0.70 (0.52-0.82) | 0.70 (0.51-0.77) | 2.3 (1.7-2.7) | 0.43 (0.34-0.67)
With additional data | 6^b^ | 0.64 (0.52-0.82) | 0.69 (0.51-0.77) | 2.0 (1.7-2.7) | 0.53 (0.34-0.67)
API ≥6.0 | 5/3^c^ | 0.51 (0.19-0.75) | 0.90 (0.58-0.96) | 5.1 (1.8-7.3) | 0.54 (0.43-0.94)
With additional data | 6^b^ | 0.54 (0.19-0.75) | 0.88 (0.58-0.96) | 4.5 (1.4-7.3) | 0.52 (0.43-0.94)
APRI ≥0.5 to >0.55 | 28 | 0.81 (0.29-0.98) | 0.55 (0.10-0.94) | 1.8 (1.1-4.8) | 0.35 (0.08-0.78)
With additional data | 40^d^ | 0.79 (0.29-0.98) | 0.56 (0.10-1.0) | 1.8 (1.0-7.5) | 0.56 (0.07-0.93)
AST:ALT Ratio >1.0 | 5 | 0.35 (0.08-0.45) | 0.77 (0.62-1.0) | 1.5 (1.1-15) | 0.84 (0.84-0.98)
With additional data | 8^b,d^ | 0.36 (0.08-0.59) | 0.80 (0.48-1.0) | 1.7 (1.1-14) | 0.81 (0.65-0.98)
ELF >8.75 >9.0, or >9.78 | 3 | 0.85 (0.84-0.86) | 0.70 (0.62-0.80) | 2.8 (2.3-4.2) | 0.21 (0.19-0.23)
With additional data | 3^b^ | 0.84 (0.62-0.85) | 0.80 (0.70-0.86) | 4.2 (2.8-4.4) | 0.20 (0.19-0.45)
FIB-4 >1.26 or ≥1.45 | 6 | 0.64 (0.62-0.86) | 0.68 (0.54-0.75) | 2.0 (0.88-2.6) | 0.53 (0.21-1.3)
With additional data | 9^d^ | 0.64 (0.57-0.86) | 0.68 (0.28-0.85) | 2.0 (0.88-3.7) | 0.53 (0.21-1.3)
FIB-4 >3.25 | 4 | 0.50 (0.28-0.86) | 0.79 (0.59-0.99) | 2.4 (1.3-28) | 0.63 (0.21-0.80)
With additional data | 7^d^ | 0.28 (0.11-0.86) | 0.97 (0.59-1.0) | 9.3 (1.3-28) | 0.74 (0.21-0.89)
FibroIndex >1.25 | 3 | 0.94 (0.62-0.97) | 0.40 (0.40-0.48) | 1.6 (1.2-1.6) | 0.15 (0.08-0.79)
With additional data | 6^d^ | 0.64 (0.54-0.97) | 0.57 (0.40-1.0) | 1.5 (1.2-2.2) | 0.62 (0.08-0.79)
FibroIndex >2.25 or ≥2.25 | 3 | 0.30 (0.17-0.36) | 0.97 (0.97-1.0) | 10,12,∞ | 0.72 (0.66-0.83)
With additional data | 4^d^ | 0.24 (0.14-0.36) | 0.99 (0.97-1.0) | 10,12,∞ | 0.78 (0.66-0.87)
Fibrometer >0.419 to >0.59 | 3 | 0.69 (0.64-0.80) | 0.81 (0.76-0.81) | 3.6 (3.4-3.6) | 0.38 (0.26-0.44)
With additional data | 5^d^ | 0.80 (0.64-0.87) | 0.76 (0.64-0.81) | 3.3 (2.4-3.6) | 0.26 (0.21-0.44)
FibroTest >0.10 to >0.22 | 6 | 0.92 (0.88-0.97) | 0.38 (0.27-0.56) | 1.5 (1.3-1.9) | 0.21 (0.11-0.28)
With additional data | 9^d^ | 0.92 (0.64-0.98) | 0.46 (0.21-1.0) | 1.7 (1.2-2.2) | 0.17 (0.11-0.39)
FibroTest >0.70 or >0.80 | 5 | 0.22 (0.20-0.50) | 0.96 (0.95-0.98) | 5.5 (5.5-13) | 0.81 (0.53-0.82)
With additional data | 10^b,d^ | 0.38 (0.20-0.94) | 0.95 (0.36-0.98) | 7.6 (1.4-13) | 0.65 (0.12-0.82)
Forns Index >4.2 to >4.57 | 14 | 0.88 (0.57-0.94) | 0.52 (0.20-0.77) | 1.8 (1.2-2.2) | 0.22 (0.12-0.64)
With additional data | 16^b,d^ | 0.89 (0.42-0.94) | 0.51 (0.20-0.77) | 1.8 (0.54-2.2) | 0.23 (0.12-2.6)
Forns Index >6.9 | 10 | 0.36 (0.18-0.61) | 0.94 (0.66-1.0) | 6.5 (1.6-18) | 0.68 (0.56-0.92)
With additional data | 14^d^ | 0.40 (0.18-0.81) | 0.95 (0.33-1.0) | 7.4 (1.2-18) | 0.63 (0.22-0.92)
Hepascore >0.46 to ≥0.55 | 5 | 0.66 (0.54-0.82) | 0.79 (0.65-0.86) | 3.1 (2.3-4.5) | 0.43 (0.28-0.55)
With additional data | 8^d^ | 0.65 (0.54-0.82) | 0.80 (0.65-0.86) | 3.2 (2.3-4.5) | 0.44 (0.28-0.55)
Lok Index >0.17 or >0.20 | 0 | NA | NA | NA | NA
With additional data | 3^d^ | 0.58 (0.48-0.82) | 0.80 (0.58-0.81) | 2.9 (2.0-3.1) | 0.53 (0.31-0.65)

ALT = serum alanine aminotransferase; API = age platelet index; APRI = aspartate aminotransferase to platelet ratio index; AST = aspartate aminotransferase; ELF = enhanced liver fibrosis.

a Values in bold indicate a change to above or below a cutoff of 5.0 for positive likelihood ratio or 0.20 for negative likelihood ratio

b Additional data for study(s) with discrepancy in reported data

c 5 samples for sensitivity, 3 for specificity

d Additional data for study(s) without 2 × 2 tables

For diagnosing cirrhosis, additional data was provided for eight tests, four of which were evaluated at two different cutoffs (Table 2). For the APRI at a cutoff of >1.0 or >=1.0 data was available for 10 additional studies, but the effect on median likelihood ratio estimates was minimal. The number of additional studies ranged from one to five for other blood tests and cutoffs. For the Lok Index, the negative likelihood ratio based on a cutoff of >=0.20 or >0.26 was re-classified from less useful to moderately useful, but the impact on the estimate was minimal (0.21 in the original analysis and 0.19 with additional data). Similarly, the positive likelihood ratios for the Lok Index based on a cutoff of >=0.5 or >0.6 and the AST/ALT ratio with a cutoff of >1.0 were reclassified from less useful to moderately useful, but the impact on the estimate was also relatively small (4.4 to 5.8; 4.5 to 5.6, respectively).

Table 2 Diagnostic accuracy of tests for cirrhosis^a^

Fibrosis Test (cutoff) | Number of Samples | Sensitivity (median, range) | Specificity (median, range) | Positive Likelihood Ratio (median, range) | Negative Likelihood Ratio (median, range)
Platelets <140 to <155 | 9 | 0.78 (0.41-0.93) | 0.87 (0.84-0.94) | 6.0 (2.8-93) | 0.25 (0.07-0.63)
With additional data | 10^b^ | 0.77 (0.41-0.93) | 0.86 (0.57-0.99) | 5.5 (1.6-93) | 0.27 (0.07-0.63)
API ≥6.0 | 5/3^c^ | 0.67 (0.43-0.80) | 0.87 (0.81-0.93) | 5.2 (2.7-10) | 0.38 (0.22-0.68)
With additional data | 6^b^ | 0.64 (0.12-0.80) | 0.88 (0.81-0.99) | 5.3 (2.7-17) | 0.41 (0.22-0.88)
APRI >1.0 or ≥1.0 | 19 | 0.77 (0.33-1.0) | 0.75 (0.30-0.87) | 3.1 (1.4-4.9) | 0.31 (0-0.77)
With additional data | 30/29^c,d^ | 0.75 (0.13-1.0) | 0.77 (0.30-1.0) | 3.2 (1.4-10.6) | 0.33 (0-0.89)
AST:ALT Ratio >1.0 | 17 | 0.36 (0.12-0.78) | 0.92 (0.59-1.0) | 4.5 (1.0-31) | 0.70 (0.47-1.0)
With additional data | 19^b^ | 0.39 (0.10-0.78) | 0.93 (0.59-1.0) | 5.6 (1.0-31) | 0.66 (0.23-1.0)
FIB-4 >1.45 | 1 | 0.90 | 0.58 | 2.1 | 0.17
With additional data | 4^d^ | 0.89 (0.87-1.0) | 0.58 (0.40-0.70) | 2.1 (1.7-2.9) | 0.19 (0.0-0.23)
FIB-4 >3.25 | 1 | 0.55 | 0.92 | 6.9 | 0.49
With additional data | 5^d^ | 0.49 (0.40-0.55) | 0.93 (0.91-0.95) | 6.4 (5.7-8.9) | 0.60 (0.49-0.63)
FibroTest >0.56 or >0.66 | 2 | 0.85 & 0.82 | 0.74 & 0.77 | 3.3 & 36 | 0.20 & 0.23
With additional data | 7^d^ | 0.83 (0.27-0.91) | 0.74 (0.65-1.0) | 3.6 (2.6-3.6) | 0.23 (0.11-0.73)
FibroTest >0.73, >0.75, >0.862 | 7 | 0.56 (0.30-1.0) | 0.81 (0.24-0.96) | 2.9 (1.2-10) | 0.54 (0.0-0.79)
With additional data | 10^b,d^ | 0.49 (0.11-0.86) | 0.89 (0.55-1.0) | 4.3 (1.2-11) | 0.57 (0.20-0.89)
Forns Index >4.2 | 1 | 0.98 | 0.27 | 1.3 | 0.07
With additional data | 6^d^ | 0.66 (0.27-1.0) | 0.31 (0-1.0) | 1.4 (0.27-1.5) | 0.07 (0-0.66)
Forns Index >6.9 | 1 | 0.67 | 0.91 | 7.4 | 0.36
With additional data | 3^d^ | 0.66 (0.53-0.67) | 0.87 (0.86-0.91) | 5.2 (4.2-7.4) | 0.39 (0.36-0.53)
Lok Index ≥0.20 or >0.26 | 6 | 0.90 (0.67-1.0) | 0.50 (0.30-0.82) | 1.8 (1.0-4.8) | 0.21 (0-0.94)
With additional data | 7^d^ | 0.90 (0.67-1.0) | 0.53 (0.30-0.82) | 1.9 (1.0-4.8) | 0.19 (0-0.94)
Lok Index ≥0.5 or >0.6 | 7 | 0.53 (0.40-0.79) | 0.88 (0.60-0.95) | 4.4 (1.3-11) | 0.53 (0.24-0.80)
With additional data | 8^d^ | 0.53 (0.23-0.79) | 0.91 (0.60-0.97) | 5.8 (1.3-11) | 0.52 (0.24-0.80)

ALT = serum alanine aminotransferase; API = age platelet index; APRI = aspartate aminotransferase to platelet ratio index; AST = aspartate aminotransferase; ELF = enhanced liver fibrosis.

a Values in bold indicate a change to above or below a cutoff of 5.0 for positive likelihood ratio or 0.20 for negative likelihood ratio

b Additional data for study(s) with discrepancy in reported data

c first number is number of samples for sensitivity/second number is number of samples for specificity

d Additional data for study(s) without 2 × 2 tables

We compared the effects of additional data from studies with discrepancies with the effects of additional data from studies in which 2 × 2 tables could not be generated and found no clear pattern suggesting differential effects on median estimates. We also evaluated effects of additional data with respect to the original strength of evidence ratings. No test for which we obtained additional data was originally rated low strength of evidence. The two tests for which additional data resulted in the greatest changes, the FIB-4 and the FibroIndex, were both originally rated as moderate strength of evidence. For diagnosis of fibrosis, the number of studies increased from four to seven and from three to six, respectively. For tests originally rated as high strength of evidence (APRI, AST/ALT ratio, Fibrotest), new evidence had little impact on median estimates. Analyses on the effects of year of publication, study quality, country, or other factors on changes in estimates were too limited by the small number of studies available for most blood tests and cutoffs to draw reliable conclusions.

The overall strength of evidence rating did not change for any of the tests for which we obtained additional data, due to the relatively small number of studies providing additional data for most tests. All were rated as moderate or high strength of evidence in the original systematic review. We received the most additional data for the APRI, which was already rated high strength of evidence.