# References

1 Chou R, Clark EC, Helfand M. Screening for hepatitis C virus infection: A review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(6):465-79. [pmid: 15023713].
2 Regev A, Berho M, Jeffers LJ, et al. Sampling error and intraobserver variation in liver biopsy in patients with chronic HCV infection. Am J Gastroenterol. Oct. 2002;97(10):2614-8. [pmid: 12385448].
3 Chou R, Cottrell EB, Wasson N, et al. Screening for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review No. 9. (Prepared by the Oregon Evidence-based Practice Center under contract No. 290-2007-10057-I). Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. [pmid: 23304739]. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Chou R, Cottrell EB, Wasson N, et al. Screening for hepatitis C virus infection in adults: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. Jan. 15. 2013;158(2):101-8. [pmid: 23183613].
5 Chou R, Wasson N. Blood tests to diagnose fibrosis or cirrhosis in patients with chronic hepatitis C virus infection. Ann Intern Med. Sep. 3. 2013;159(5):372. [pmid: 24026329].
6 Wolfe N, Gotzsche PC, Bero L. Strategies for obtaining unpublished drug trial data: a qualitative interview study. Syst Rev. 2013;2:31. [pmid: 23680054].
7 Attallah AM, Abdallah SO, Attallah AA, et al. Diagnostic value of fibronectin discriminant score for predicting liver fibrosis stages in chronic hepatitis C virus patients. Ann Hepatol. Jan. 2013;12(1):44-53. [pmid: 23293193].
8 Attallah AM, Omran MM, Farid K, et al. Development of a novel score for liver fibrosis staging and comparison with eight simple laboratory scores in large numbers of HCV-monoinfected patients. Clin Chim Acta. Nov. 12. 2012;413(21-22):1725-30. [pmid: 22759976].
9 Cheung KJ, Tilleman K, Deforce D, et al. Usefulness of a novel serum proteome-derived index FI-PRO (fibrosis-protein) in the prediction of fibrosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2011;23(8):701-10. [pmid: 21623191].
10 Ben Jazia E, Kaabia N, Benabdelkader A, et al. Noninvasive fibrosis markers for the prediction of significant fibrosis in patients with chronic hepatitis C virus infection in Tunisia. Infect Dis Clin Pract (Baltim Md). 2009;17(6):385-7.
11 Crisan D, Radu C, Lupsor M, et al. Two or more synchronous combination of noninvasive tests to increase accuracy of liver fibrosis assessement in chronic Hepatitis C; results from a cohort of 446 patients. Hepat Mon. 2012;12(3):177-84. [pmid: 22550525].
12 Ehsan N, Badr M, Raouf A, et al. Correlation between liver biopsy findings and different serum biochemical tests in staging fibrosis in Egyptian patients with chronic hepatitis C virus infection. Arab J Gastroenterol. 2008;9(1):7-12.
13 El-mezayen HA, Toson el SA, Shiha GE. Role of hyaluronic acid, its degrading enzymes, degradation products, and ferritin in the assessment of fibrosis stage in Egyptian patients with chronic hepatitis C. Eur J Gastroenterol Hepatol. Jan. 2013;25(1):69-76. [pmid: 23011038].
14 Guechot J, Trocme C, Renversez JC, et al. Independent validation of the Enhanced Liver Fibrosis (ELF) score in the ANRS HC EP 23 Fibrostar cohort of patients with chronic hepatitis C. Clinical Chemistry & Laboratory Medicine. Apr. 2012;50(4):693-9. [pmid: 22505560].
15 Iacobellis A, Fusilli S, Mangia A, et al. Ultrasonographic and biochemical parameters in the non-invasive evaluation of liver fibrosis in hepatitis C virus chronic hepatitis. Aliment Pharmacol Ther. 2005;22(9):769-74. [pmid: 16225484].
16 Iacobellis A, Mangia A, Leandro G, et al. External validation of biochemical indices for noninvasive evaluation of liver fibrosis in HCV chronic hepatitis. Am J Gastroenterol. 2005;100(4):868-73. [pmid: 15784034].
17 Leroy V, Monier F, Bottari S, et al. Circulating matrix metalloproteinases 1, 2, 9 and their inhibitors TIMP-1 and TIMP-2 as serum markers of liver fibrosis in patients with chronic hepatitis C: comparison with PIIINP and hyaluronic acid. Am J Gast. 2004;99(2):271-9. [pmid: 15046217].
18 Mossong J, Bill S, Hawotte K, et al. Predicting significant fibrosis in hepatitis C patients in Luxembourg using serological markers. Bull Soc Sci Med Grand Duche Luxemb. 2011;(1):19-30. [pmid: 21634219].
19 Saitou Y, Shiraki K, Yamanaka Y, et al. Noninvasive estimation of liver fibrosis and response to interferon therapy by a serum fibrogenesis marker, YKL-40, in patients with HCV-associated liver disease. World J Gastroenterol. 2005;11(4):476-81. [pmid: 15641129].
20 Sebastiani G, Vario A, Guido M, et al. Performance of noninvasive markers for liver fibrosis is reduced in chronic hepatitis C with normal transaminases. J Vir Hep. 2008;15(3):212-8. [pmid: 18179453].
21 Sebastiani G, Castera L, Halfon P, et al. The impact of liver disease aetiology and the stages of hepatic fibrosis on the performance of non-invasive fibrosis biomarkers: an international study of 2411 cases. Aliment Pharmacol Ther. 2011;34(10):1202-16. [pmid: 21981787].
22 Sebastiani G, Halfon P, Castera L, et al. Comparison of three algorithms of non-invasive markers of fibrosis in chronic hepatitis C. Aliment Pharmacol Ther. 2012;35(1):92-104. [pmid: 22035045].
23 Stibbe KJM, Verveer C, Francke J, et al. Comparison of non-invasive assessment to diagnose liver fibrosis in chronic hepatitis B and C patients. Scand J Gastroenterol. Jul. 2011;46(7-8):962-72. [pmid: 21623677].
24 Park SH, Kim CH, Kim DJ, et al. Diagnostic value of multiple biomarker panel for prediction of significant fibrosis in chronic hepatitis C. Clin Biochem. 2011;44(17-18):1396-9. [pmid: 21971609].
25 Park JJ, Park JY, Kim do Y, et al. Prediction of significant fibrosis in chronic hepatitis C patients with normal ALT. Hepatogastroenterology. Jul-Aug. 2011;58(109):1321-7. [pmid: 21937403].
26 Cheung RC, Currie S, Shen H, et al. Can we predict the degree of fibrosis in chronic hepatitis C patients using routine blood tests in our daily practice?. J Clin Gastroenterol. 2008;42(7):827-34. [pmid: 18285716].
27 Shlomai A, Halfon P, Goldiner I, et al. Serum bile acid levels as a predictor for the severity of liver fibrosis in patients with chronic hepatitis C. J Viral Hepat. Feb. 2013;20(2):95-102. [pmid: 23301544].
28 Zarski JP, Sturm N, Guechot J, et al. Comparison of nine blood tests and transient elastography for liver fibrosis in chronic hepatitis C: the ANRS HCEP-23 study. J Hepatol. Jan. 2012;56(1):55-62. [pmid: 21781944].
29 Bota S, Sirli R, Sporea I, et al. A new scoring system for prediction of fibrosis in chronic hepatitis C. Hepat Mon. 2011;11(7):548-55. [pmid: 22087193].
30 Friedrich-Rust M, Rosenberg W, Parkes J, et al. Comparison of ELF, FibroTest and FibroScan for the non-invasive assessment of liver fibrosis. BMC Gastroenterology. 2010;10(1):103. [pmid: 20828377].
31 Lu SN, Wang JH, Liu SL, et al. Thrombocytopenia as a surrogate for cirrhosis and a marker for the identification of patients at high-risk for hepatocellular carcinoma. Cancer. Nov. 1. 2006;107(9):2212-22. [pmid: 17019738].
32 Omran MM, Farid K, Emran TM, et al. Fibro-(alpha) score as a simple and useful non-invasive test for predicting significant liver fibrosis in chronic hepatitis C patients. Arab J Gastroenterol. 2011;12(2):74-9. [pmid: 21684477].
33 Adler M, Gulbis B, Moreno C, et al. The predictive value of FIB-4 versus FibroTest, APRI, FibroIndex and Forns index to noninvasively estimate fibrosis in hepatitis C and nonhepatitis C liver diseases. Hepatology. 2008;47(2):762-3. [pmid: 18220307].
34 Arabul M, Aslan F, Alper E, et al. Simple non-invasive markers as a predictor of fibrosis and viral response in chronic hepatitis C patients. Turk J Gastroenterol. 2012;23(5):538-45. [pmid: 23161299].
35 Calès P, De Ledinghen V, Halfon P, et al. Evaluating the accuracy and increasing the reliable diagnosis rate of blood tests for liver fibrosis in chronic hepatitis C. Liver Int. 2008;28(10):1352-62. [pmid: 18492022].
36 Cales P, Oberti F, Michalak S, et al. A novel panel of blood markers to assess the degree of liver fibrosis. Hepatology. 2005;42(6):1373-81. [pmid: 16317693].
37 Castera L, Sebastiani G, Le Bail B, et al. Prospective comparison of two algorithms combining non-invasive methods for staging liver fibrosis in chronic hepatitis C. J Hepatol. 2010;52(2):191-8. [pmid: 20006397].
38 El-Sayed R, Fahmy M, El Koofy N, et al. Can aspartate aminotransferase to platelet ratio index replace liver biopsy in chronic hepatitis C?. Trop Gastroenterol. 2011;32(4):267-72. [pmid: 22696906].
39 Gabrielli GB, Capra F, Casaril M, et al. Serum laminin and type III procollagen in chronic hepatitis C. Diagnostic value in the assessment of disease activity and fibrosis. Clin Chim Acta. 1997;265(1):21-31. [pmid: 9352126].
40 Halfon P, Bacq Y, De Muret A, et al. Comparison of test performance profile for blood tests of liver fibrosis in chronic hepatitis C. J Hepatol. 2007;46:395-402. [pmid: 17156890].
41 Halfon P, Penaranda G, Renou C, et al. External validation of FibroIndex. Hepatology. Jul. 2007;46(1):280-1. author reply 1-2. [pmid: 17596884].
42 Morali G, Maor Y, Klar R, et al. Fibrotest-Actitest: the biochemical marker of liver fibrosis--the Israeli experience. Isr Med Assoc J. 2007;9:588-91. [pmid: 17877064].
43 Rosenberg W, Voelker M, Thiel R, et al. Serum markers detect the presence of liver fibrosis: a cohort study. Gastroenterology. 2004;127:1704-13. [pmid: 15578508].
44 Jaeschke R, Guyatt GH, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. Mar. 2. 1994;271(9):703-7. [pmid: 8309035].
45 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(13)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2013. Chapters available at: www.effectivehealthcare.ahrq.gov.
46 Calès P, Boursier J, Bertrais S, et al. Optimization and robustness of blood tests for liver fibrosis and cirrhosis. Clin Biochem. 2010;43(16-17):1315-22. [pmid: 20713037].
47 Amorim TG, Staub GJ, Lazzarotto C, et al. Validation and comparison fo simple noninvasive models for the prediction of liver fibrosis in chronic hepatitis C. Ann Hepatol. 2012;11:855-61. [pmid: 23109448].
48 Bourliere M, Penaranda G, Ouzan D, et al. Optimized stepwise combination algorithms of non-invasive liver fibrosis scores including Hepascore in hepatitis C virus patients. Aliment Pharmacol Ther. 2008;28(4):458-67. [pmid: 18498446].
49 Boursier J, Bacq Y, Halfon P, et al. Improved diagnostic accuracy of blood tests for severe fibrosis and cirrhosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2009;21(1):28-38. [pmid: 19060630].
50 Boursier J, de Ledinghen V, Zarski JP, et al. A new combination of blood test and fibroscan for accurate non-invasive diagnosis of liver fibrosis stages in chronic hepatitis C. Am J Gastroenterol. 2011;106(7):1255-63. [pmid: 21468012].
51 Burton MJ, Sunesara I, Penman A, et al. Comparing the aspartate aminotransferase (AST) to platelet ratio index (APRI) between African American and white veterans with chronic hepatitis C. South Med J. 2011;104(5):309-14. [pmid: 21606706].
52 Gara N, Zhao X, Kleiner DE, et al. Discordance among transient elastography, aspartate aminotransferase to platelet ratio index, and histologic assessments of liver fibrosis in patients with chronic hepatitis C. Clin Gastroenterol Hepatol. Mar. 2013;11(3):303-8.e1. [pmid: 23142332].
53 Giannini (b) E, Testa R. Noninvasive diagnosis of fibrosis: The truth is rarely pure and never simple. Hepatology. 2003;38(5):1312-3. [pmid: 14578874].
54 Ichino N, Osakabe K, Nishikawa T, et al. A new index for non-invasive assessment of liver fibrosis. World J Gastroenterol. 2010;16(38):4809-16. [pmid: 20939109].
55 Patel K, Benhamou Y, Yoshida EM, et al. An independent and prospective comparison of two commercial fibrosis marker panels (HCV FibroSURE and FIBROSpect II) during albinterferon alfa-2b combination therapy for chronic hepatitis C. J Vir Hep. 2009;16(3):178-86. [pmid: 19175870].
56 Sirli R, Sporea I, Bota S, et al. A comparative study of non-invasive methods for fibrosis assessment in chronic HCV infection. Hepat Mon. 2010;10(2):88-94. [pmid: 22312379].
57 Testa R, Testa E, Giannini E, et al. Noninvasive ratio indexes to evaluate fibrosis staging in chronic hepatitis C: role of platelet count/spleen diameter ratio index. J Int Med. 2006;260(2):142-50. [pmid: 16882278].
58 Wilson LE, Torbenson M, Astemborski J, et al. Progression of liver fibrosis among injection drug users with chronic hepatitis C. Hepatology. 2006;43(4):788-95. [pmid: 16557548].
59 Yilmaz Y, Yonal O, Kurt R, et al. Noninvasive assessment of liver fibrosis with the aspartate transaminase to platelet ratio index (APRI): usefulness in patients with chronic liver disease. Hepat Mon. 2011;11(2):103-7. [pmid: 22087126].
60 Cross TJ, Calvaruso V, Maimone S, et al. Prospective comparison of Fibroscan, King's score and liver biopsy for the assessment of cirrhosis in chronic hepatitis C infection. J Viral Hepat. 2010;17(8):546. [pmid: 19874477].
61 Cross TJS, Rizzi P, Berry PA, et al. King's Score: an accurate marker of cirrhosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2009;21(7):730-8. [pmid: 19430302].
62 Deghady A, Abdou A, El-Neanaey WA, et al. Association of genetic polymorphism -670A>G in the Fas gene and serum markers AST platelet ratio index, AST/ALT with significant fibrosis and cirrhosis in chronic hepatitis C. Genet Test Mol Biomarkers. Jun. 2012;16(6):531-5. [pmid: 22352690].
63 Fontanges T, Bailly F, Trepo E, et al. Discordance between biochemical markers of liver activity and fibrosis (Actitest-Fibrotest) and liver biopsy in patients with chronic hepatitis C. Gastroenterol Clin Biol. Oct. 2008;32(10):858-65. [pmid: 18775614].
64 Grigorescu M, Rusu M, Neculoiu D, et al. The FibroTest value in discriminating between insignificant and significant fibrosis in chronic hepatitis C patients. The Romanian experience. J Gastrointestin Liver Dis. 2007;16(1):31-7. [pmid: 17410286].
65 Islam S, Antonsson L, Westin J, et al. Cirrhosis in hepatitis C virus-infected patients can be excluded using an index of standard biochemical serum markers. Scand J Gastroenterol. 2005;40(7):867-72. [pmid: 16109665].
66 Morra R, Munteanu M, Bedossa P, et al. Diagnostic value of serum protein profiling by SELDI-TOF ProteinChip compared with a biochemical marker, FibroTest, for the diagnosis of advanced fibrosis in patients with chronic hepatitis C. Aliment Pharmacol Ther. Sep. 15. 2007;26(6):847-58. [pmid: 17767469].
67 Parkes J, Guha I, Roderick P, et al. Enhanced Liver Fibrosis (ELF) test accurately identifies liver fibrosis in patients with chronic hepatitis C. J Viral Hepatitis. 2010;18(1):23-31. [pmid: 20196799].
68 Cobbold J, Crossey M, Colman P, et al. Optimal combinations of ultrasound-based and serum markers of disease severity in patients with chronic hepatitis C. J Viral Hepat. 2010;17(8):537-45. [pmid: 19804501].
69 Ahmad W, Ijaz B, Javed FT, et al. A comparison of four fibrosis indexes in chronic HCV: development of new fibrosis-cirrhosis index (FCI). BMC Gastroenterology. 2011;11:44. [pmid: 21507271].
70 Poynard T, McHutchison J, Manns M, et al. Biochemical surrogate markers of liver fibrosis and activity in a randomized trial of peginterferon alfa-2b and ribavirin. Hepatology. 2003;38:481-92. [pmid: 12883493].
71 Schneider AR, Teuber G, Paul K, et al. Patient age is a strong independent predictor of 13C-aminopyrine breath test results: a comparative study with histology, duplex-Doppler and a laboratory index in patients with chronic hepatitis C virus infection. Clin Exp Pharmacol Physiol. 2006;33(4):300-4. [pmid: 16620291].
72 Fouad SA, Esmat S, Omran D, et al. Noninvasive assessment of hepatic fibrosis in Egyptian patients with chronic hepatitis C virus infection. World J Gastroenterol. Jun. 21. 2012;18(23):2988-94. [pmid: 22736923].
73 Loaeza-del-Castillo A, Paz-Pineda F, Oviedo-Cárdenas E, et al. AST to platelet ratio index (APRI) for the noninvasive evaluation of liver fibrosis. Ann Hepatol. 2008;7(4):350-7. [pmid: 19034235].
74 Hsieh YY, Tung SY, Lee K, et al. Routine blood tests to predict liver fibrosis in chronic hepatitis C. World J Gastroenterol. Feb. 28. 2012;18(8):746-53. [pmid: 22371634].
75 Imbert-Bismut F, Ratziu V, Laurence Pieroni L, et al. Biochemical markers of liver fibrosis in patients with hepatitis C virus infection: a prospective study. Lancet. 2001;357:1069-75. [pmid: 11297957].
76 Parise ER, Oliveira AC, Figueiredo-Mendes C, et al. Noninvasive serum markers in the diagnosis of structural liver damage in chronic hepatitis C virus infection. Liver Int. 2006;26(9):1095-9. [pmid: 17032410].
77 Viana MSVB. Use of AST platelet ratio index (APRI Score) as an alternative to liver biopsy for treatment indication in chronic hepatitis C. Ann Hepatol. Jan-Mar. 2009;8(1):26-31. [pmid: 19221530].
78 Castéra L, Vergniol J, Foucher J, et al. Prospective comparison of transient elastography, Fibrotest, APRI, and liver biopsy for the assessment of fibrosis in chronic hepatitis C. Gastroenterology. 2005;128(2):343-50. [pmid: 15685546].
79 Fabris C, Smirne C, Toniutto P, et al. Usefulness of six non-proprietary indirect markers of liver fibrosis in patients with chronic hepatitis C. Clin Chem Lab Med. 2008;46(2):253-9. [pmid: 18324909].
80 Fontana RJ, Goodman ZD, Dienstag JL, et al. Relationship of serum fibrosis markers with liver fibrosis stage and collagen content in patients with advanced chronic hepatitis C. Hepatology. 2008;47(3):789-98. [pmid: 18175357].
81 Lackner C, Struber G, Liegl B, et al. Comparison and validation of simple noninvasive tests for prediction of fibrosis in chronic hepatitis C. Hepatology. 2005;41(6):1376-82. [pmid: 15915455].
82 Martinez SM, Fernández-Varo G, González P, et al. Assessment of liver fibrosis before and after antiviral therapy by different serum marker panels in patients with chronic hepatitis C. Aliment Pharmacol Ther. 2011;33(1):138-48. [pmid: 21083589].
83 Snyder N, Gajula L, Xiao SY, et al. APRI: An easy and validated predictor of hepatic fibrosis in chronic hepatitis C. J Clin Gastroenterol. 2006;40(6):535-42. [pmid: 16825937].
84 Snyder N, Nguyen A, Gajula L, et al. The APRI may be enhanced by the use of the FIBROSpect II in the estimation of fibrosis in chronic hepatitis C. Clinica Chimica Acta. 2007;381(2):119-23. [pmid: 17442291].
85 Westin J, Ydreborg M, Islam S, et al. A non-invasive fibrosis score predicts treatment outcome in chronic hepatitis C infection. Scand J Gastroenterol. 2008;43:78-80.
86 Lok AS, Ghany MG, Goodman ZD, et al. Predicting cirrhosis in patients with hepatitis C based on standard laboratory tests: results of the HALT-C cohort. Hepatology. Aug. 2005;42(2):282-92. [pmid: 15986415].