# Methods

We sent letters to 66 corresponding authors asking for additional information or clarification of data from 77 studies that had discrepancies in the data reported (n=17)7-23 or that provided insufficient data to construct 2 × 2 tables at standard cutoffs (n=60).9, 24-43 See Appendix A for a list of studies included in this report and Appendix B for a sample of the letter sent to authors. We defined studies with discrepancies as those in which reported measures of diagnostic accuracy were inconsistent with measures of diagnostic accuracy calculated from 2 × 2 tables by values of >0.10 (e.g., reported positive predictive value of 0.85 vs. calculated positive predictive value of 0.70). (See “Table 3 of the Supplement. Discrepancies” published as an online supplement to the review.5) For studies in which 2 × 2 table data were not provided, we calculated values for 2 × 2 tables for commonly reported cutoff values for a positive test, based on the reported sample size, prevalence of the condition of interest (fibrosis or cirrhosis), sensitivity, and specificity. Studies for which we could not construct 2 × 2 tables included those in which some measures of diagnostic accuracy were reported, but other necessary information was missing (e.g., sample size, prevalence of condition), studies in which sensitivity and specificity were reported at nonstandard cutoffs, and studies in which only an AUROC was reported, without sensitivity or specificity or other measures of diagnostic accuracy at specific cutoffs.

For studies with discrepancies and cases in which we could not construct a 2 × 2 table, we requested that authors provide the 2 × 2 data used to generate their estimates of diagnostic accuracy. For studies that provided only AUROC or did not report diagnostic accuracy at standard cutoffs, we asked that authors provide 2 × 2 data for diagnostic accuracy at standard cutoffs for the blood test or tests evaluated.

If there was no response to our initial email, after a minimum of 3 business days we sent a second reminder email to the corresponding author. If there was still no response after a minimum of 8 business days following the initial email, we sent a second reminder email. After a minimum of 10 business days with no response, we then attempted to contact authors by telephone. If still unable to reach corresponding authors, we attempted to contact last authors and statisticians, if identifiable. If corresponding authors forwarded our request to other authors, we sent reminders to these authors. After a minimum of 15 business days from our initial email, we sent a final email to authors. If we received an automated “out-of-office” response, we waited until the author had returned to send further reminders. In all cases, for the convenience of authors, we provided labeled 2×2 tables that they could fill in and send back to us. We tracked responses in a Microsoft Excel^®^ spreadsheet.

As in the original review, we considered clinically significantly fibrosis to be F2 to F4 on the Meta-analysis of Histological Data in Viral Hepatitis (METAVIR) scale, a score of 3 to 6 on the Ishak scale, or equivalent. We considered F4 on the METAVIR scale, a score of 5 to 6 on the Ishak scale, or equivalent to indicate liver cirrhosis. We recalculated median values and ranges for sensitivity and specificity at the cutoffs used in the original review using additional data obtained, and we compared differences between the updated and original findings. As in the original review, we categorized blood tests reporting a positive likelihood ratio of 5 to 10 or a negative likelihood ratio of 0.1 to 0.2 as moderately useful (no blood test was associated with a positive likelihood ratio of >10 or negative likelihood ratio <0.1).44 We also re-rated the strength of evidence with the additional data, in accordance with the Agency for Healthcare Research and Quality “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”45