# Acknowledgments

We would like to thank the following corresponding and other authors for responding to our request for additional study data:

Alfredo Alberti, M.D., Simona Bota, M.D., Marc Bourlière, M.D., Jérôme Boursier, M.D., Rafael Bruck, M.D., Mary J. Burton, M.D., Paul Calès, M.D., Laurent Castera, M.D., Ramsey C. Cheung, M.D., Kin Jip Cheung, Ph.D., Dana Crisan, M.D., Ph.D., Mireen Friedrich-Rust, M.D., Naveen Gara, M.D., Edoardo G. Giannini, M.D., Ph.D., Mircea Grigorescu, M.D., Ph.D., Jérôme Guéchot , Pharm.D., Ph.D., Kwang-Hyub Han, M.D., Philippe Halfon, M.D. Ph.D., Pharm.D., Angelo Iacobellis, M.D., Dong Joon Kim, M.D., Sheng-Nan Lu, M.D., M.P.H., Ph.D., Gilles Morali, M.D., Joel Mossong, PhD., Rokaya Mohamed El-Sayed, M.D., Mohamed M. Omran, Ph.D., Jae Jun Park, M.D., Keyur Patel, M.D., Ph.D., Guillaume Pénaranda, M.Sc., William Rosenberg, Ph.D., Christoph Sarrazin, M.D., Leonardo L. Schiavon, M.D., Ph.D., Giada Sebastiani, M.D., Roxana Sirli, M.D., Ph.D., Roberto Testa, M.D., David L. Thomas, M.D., M.P.H., Hans Van Vlierberghe, M.D., Ph.D., Hanneke van Vuuren, Ph.D., Kentaro Yoshioka, M.D., Ph.D., Yusuf Yilmaz, M.D., and Jean-Pierre Zarski, M.D., Ph.D.