# Discussion

Our experience in attempting to contact authors and acquire additional information in a systematic review of diagnostic tests is encouraging. We were able to contact the majority of authors, particularly for papers published within the last few years. Most contacted authors provided data, and several more would have likely complied with our request had the data been more readily accessible to them. However, this effort was time consuming, not only for us, but also for study authors, who often had to first locate the data before being able to complete the 2 × 2 tables. In addition, despite our efforts, data to resolve discrepancies or calculate 2 × 2 tables at commonly used cutoffs for sensitivity and specificity could not be obtained for 48 of 77 (62 percent) studies, most frequently because authors could not be contacted or they did not have access to the data; this experience indicates that despite relatively extensive efforts to obtain additional data, unresolved discrepancies and missing data remain likely. All data were obtained with the first three out of five attempted contacts, suggesting that more extensive efforts may be of low yield. In particular, telephone contact did not produce any additional information.

The effects of requests for additional data on the results and conclusions regarding the utility of blood tests to identify patients with clinically significant fibrosis or cirrhosis were generally small. An exception was the FIB-4 at a threshold of >3.25 for fibrosis, for which the median positive likelihood ratio increased from 2.4 to 9.3 (moving into the moderately useful range), and the FibroIndex >1.25, for which the median negative likelihood ratio increased from 0.15 to 0.62 (dropping out of the moderately useful range). Although the additional information also affected the categorization for the Fibrotest, the Lok Index, the AST/ALT ratio, and the age-platelet index, the changes in the actual median likelihood ratio estimates were small, resulting in less certainty regarding the significance of the reclassifications. For the Lok Index, additional data also enabled estimation of accuracy for fibrosis. Consistent with its development as a tool to identify patients with cirrhosis,86 the Lok Index was only weakly predictive for fibrosis.

We did not identify a clear pattern for the directional impact of additional data on estimates of diagnostic accuracy. There were also no clear differences in the effects of additional data from studies with discrepancies versus those in which 2 × 2 tables could not be calculated. However, data to evaluate for such effects were too limited to draw strong conclusions.

Our results support the strength of evidence ratings as assigned in the original report, as additional data had little impact on tests rated as high strength of evidence. For tests originally rated moderate strength of evidence, effects of new data were more variable, with small changes except for the FIB-4 and FibroIndex. No test for which we obtained additional data was originally rated low strength of evidence, where one would expect the impact of additional data to be the greatest, so these results may not be applicable to systematic reviews where the majority of outcomes have low strength of evidence. The impact in such situations could be examined through simulation or modeling analyses in which random, smaller samples of the original data are used as the “base” case. However, such an analysis was outside the scope of this report. Additional data did not change strength of evidence ratings, which is unsurprising given the relatively small numbers of studies for most tests. The one test for which a large number of studies provided new data (APRI) was already rated high strength of evidence and therefore additional data could not increase the rating.

In summary, requests for additional information from authors of primary studies resulted in additional data for a systematic review of diagnostic accuracy of blood tests to identify clinically significant fibrosis or cirrhosis in patients with hepatitis C virus infection. The additional data enabled somewhat more robust estimates for diagnostic accuracy at commonly used cutoffs for a number of blood tests. Although the effects on summary estimates were relatively small in most cases, the changes had important implications in assessing the clinical utility of two tests (the FIB-4 and the FibroIndex), in one case moving a blood test into the moderately useful range and in the other case moving it out of the moderately useful range. This suggests that while including previously unpublished data can result in clinically important changes in estimates, the magnitude and direction of impact may not be readily predictable. Despite relatively extensive efforts, we were unable to obtain data to resolve discrepancies or complete 2 × 2 tables for 48 of 77 studies. Given that three attempts were needed to obtain even that level of information, more efficient mechanisms of achieving better access to information are needed. Requiring authors of studies on diagnostic accuracy to provide the 2 × 2 tables at commonly used cutoffs in the original study publication (or in the results of publically available trial registries such as ClinicalTrials.gov) would save time, enable systematic reviewers to synthesize data more readily and completely, and enable more transparent verification of authors' estimates of diagnostic accuracy.