# Sample of Letter Sent to Authors

Dear Dr. _____________,

We are researchers at the Pacific Northwest Evidence-based Practice Center at Oregon Health & Science University and are conducting a pooled analysis of diagnostic tests for liver fibrosis/cirrhosis in patients with HCV infection. We included your research in our study (Blood Tests to Diagnose Fibrosis or Cirrhosis in Patients with Chronic Hepatitis C Virus Infection, Annals of Internal Medicine, 2013; 158: 807-820) but would like to perform additional analyses based on a more complete set of data, and need more information about your study, “(insert study title)”.

We need data in order to complete the 2 × 2 table for APRI, FibroTest, FibroIndex, Forns Index and FIB-4 in patients with hepatitis C virus infection:

Fibrosis/Cirrhosis Test | Patient HAS fibrosis/cirrhosis | Patient does NOT have fibrosis/cirrhosis | Total
APRI > 0.5 for F2-F4
Positive
Negative
Total
APRI > 1.0 for F4
Positive
Negative
Total
Fibrotest cut-off 0.73 for F2-F4
Positive
Negative
Total
Fibrotest cut-off 0.73 for F4
Positive
Negative
Total
Forns > 4.2 for F2-F4
Positive
Negative
Total
Forns > 4.2 for F4
Positive
Negative
Total
Forns > 6.9 for F2-F4
Positive
Negative
Total
Forns > 6.9 for F4
Positive
Negative
Total

From your publication, we were able to abstract AUROCs but need your help with the raw numbers for the 2 × 2 tables above. We understand that we are requesting a lot of information and that you may not have time to complete the entire table. Even completing the 2 × 2 table for a few of the tests would be most helpful to us and we would be extremely grateful.

We very much appreciate any assistance you could give us with this matter. We would be happy to answer any questions you may have regarding this research.

Thank you.

Sincerely,

- Roger Chou, MD
  Director
  Pacific Northwest Evidence-based Practice Center
  Oregon Health & Science University
  Portland, Oregon
  USA
- Shelley Selph, MD
  Research Fellow
  Pacific Northwest Evidence-based Practice Center
  Oregon Health & Science University
  Portland, Oregon
  USA