# Studies Identified for Followup To Obtain Additional Data or Clarifications

1 Adler M, Gulbis B, Moreno C, et al. The predictive value of FIB-4 versus FibroTest, APRI, FibroIndex and Forns index to noninvasively estimate fibrosis in hepatitis C and nonhepatitis C liver diseases. Hepatology. 2008;47(2):762-3. [pmid: 18220307].
2 Ahmad W, Ijaz B, Javed FT, et al. A comparison of four fibrosis indexes in chronic HCV: development of new fibrosis-cirrhosis index (FCI). BMC Gastroenterology. 2011;11:44. [pmid: 21507271].
3 Amorim TG, Staub GJ, Lazzarotto C, et al. Validation and comparison fo simple noninvasive models for the prediction of liver fibrosis in chronic hepatitis C. Ann Hepatol. 2012;11:855-61. [pmid: 23109448].
4 Arabul M, Aslan F, Alper E, et al. Simple non-invasive markers as a predictor of fibrosis and viral response in chronic hepatitis C patients. Turk J Gastroenterol. 2012;23(5):538-45. [pmid: 23161299].
5 Attallah AM, Abdallah SO, Attallah AA, et al. Diagnostic value of fibronectin discriminant score for predicting liver fibrosis stages in chronic hepatitis C virus patients. Ann Hepatol. Jan. 2013;12(1):44-53. [pmid: 23293193].
6 Attallah AM, Omran MM, Farid K, et al. Development of a novel score for liver fibrosis staging and comparison with eight simple laboratory scores in large numbers of HCV-monoinfected patients. Clin Chim Acta. Nov. 12. 2012;413(21-22):1725-30. [pmid: 22759976].
7 Ben Jazia E, Kaabia N, Benabdelkader A, et al. Noninvasive fibrosis markers for the prediction of significant fibrosis in patients with chronic hepatitis C virus infection in Tunisia. Infect Dis Clin Pract (Baltim Md). 2009;17(6):385-7.
8 Bota S, Sirli R, Sporea I, et al. A new scoring system for prediction of fibrosis in chronic hepatitis C. Hepat Mon. 2011;11(7):548-55. [pmid: 22087193].
9 Bourliere M, Penaranda G, Ouzan D, et al. Optimized stepwise combination algorithms of non-invasive liver fibrosis scores including Hepascore in hepatitis C virus patients. Aliment Pharmacol Ther. 2008;28(4):458-67. [pmid: 18498446].
10 Boursier J, Bacq Y, Halfon P, et al. Improved diagnostic accuracy of blood tests for severe fibrosis and cirrhosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2009;21(1):28-38. [pmid: 19060630].
11 Boursier J, de Ledinghen V, Zarski JP, et al. A new combination of blood test and fibroscan for accurate non-invasive diagnosis of liver fibrosis stages in chronic hepatitis C. Am J Gastroenterol. 2011;106(7):1255-63. [pmid: 21468012].
12 Burton MJ, Sunesara I, Penman A, et al. Comparing the aspartate aminotransferase (AST) to platelet ratio index (APRI) between African American and white veterans with chronic hepatitis C. South Med J. 2011;104(5):309-14. [pmid: 21606706].
13 Calès P, Boursier J, Bertrais S, et al. Optimization and robustness of blood tests for liver fibrosis and cirrhosis. Clin Biochem. 2010;43(16-17):1315-22. [pmid: 20713037].
14 Calès P, Boursier J, de Lédinghen V, et al. Evaluation and improvement of a reliable diagnosis of cirrhosis by blood tests. Gastroenterologie Clinique et Biologique. 2008;32(12):1050-60. [pmid: 19019606].
15 Calès P, Oberti F, Michalak S, et al. A novel panel of blood markers to assess the degree of liver fibrosis. Hepatology. 2005;42(6):1373-81. [pmid: 16317693].
16 Castéra L, Vergniol J, Foucher J, et al. Prospective comparison of transient elastography, Fibrotest, APRI, and liver biopsy for the assessment of fibrosis in chronic hepatitis C. Gastroenterology. 2005;128(2):343-50. [pmid: 15685546].
17 Cheung KJ, Tilleman K, Deforce D, et al. Usefulness of a novel serum proteome-derived index FI-PRO (fibrosis-protein) in the prediction of fibrosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2011;23(8):701-10. [pmid: 21623191].
18 Cheung RC, Currie S, Shen H, et al. Can we predict the degree of fibrosis in chronic hepatitis C patients using routine blood tests in our daily practice?. J Clin Gastroenterol. 2008;42(7):827-34. [pmid: 18285716].
19 Cobbold J, Crossey M, Colman P, et al. Optimal combinations of ultrasound-based and serum markers of disease severity in patients with chronic hepatitis C. J Viral Hepat. 2010;17(8):537-45. [pmid: 19804501].
20 Crisan D, Radu C, Lupsor M, et al. Two or more synchronous combination of noninvasive tests to increase accuracy of liver fibrosis assessement in chronic Hepatitis C; results from a cohort of 446 patients. Hepat Mon. 2012;12(3):177-84. [pmid: 22550525].
21 Cross TJ, Calvaruso V, Maimone S, et al. Prospective comparison of Fibroscan, King's score and liver biopsy for the assessment of cirrhosis in chronic hepatitis C infection. J Viral Hepat. 2010;17(8):546-54. [pmid: 19874477].
22 Cross TJS, Rizzi P, Berry PA, et al. King's Score: an accurate marker of cirrhosis in chronic hepatitis C. Eur J Gastroenterol Hepatol. 2009;21(7):730-8. [pmid: 19430302].
23 Deghady A, Abdou A, El-Neanaey WA, et al. Association of genetic polymorphism -670A>G in the Fas gene and serum markers AST platelet ratio index, AST/ALT with significant fibrosis and cirrhosis in chronic hepatitis C. Genetic Testing & Molecular Biomarkers. Jun. 2012;16(6):531-5. [pmid: 22352690].
24 Ehsan N, Badr M, Raouf A, et al. Correlation between liver biopsy findings and different serum biochemical tests in staging fibrosis in Egyptian patients with chronic hepatitis C virus infection. Arab J Gastroenterol. 2008;9(1):7-12.
25 El-mezayen HA, Toson el SA, Shiha GE. Role of hyaluronic acid, its degrading enzymes, degradation products, and ferritin in the assessment of fibrosis stage in Egyptian patients with chronic hepatitis C. Eur J Gastroenterol Hepatol. Jan. 2013;25(1):69-76. [pmid: 23011038].
26 El-Sayed R, Fahmy M, El Koofy N, et al. Can aspartate aminotransferase to platelet ratio index replace liver biopsy in chronic hepatitis C?. Trop Gastroenterol. 2011;32(4):267-72. [pmid: 22696906].
27 Fabris C, Smirne C, Toniutto P, et al. Usefulness of six non-proprietary indirect markers of liver fibrosis in patients with chronic hepatitis C. Clin Chem Lab Med. 2008;46(2):253-9. [pmid: 18324909].
28 Fontana RJ, Goodman ZD, Dienstag JL, et al. Relationship of serum fibrosis markers with liver fibrosis stage and collagen content in patients with advanced chronic hepatitis C. Hepatology. 2008;47(3):789-98. [pmid: 18175357].
29 Fontanges T, Bailly F, Trepo E, et al. Discordance between biochemical markers of liver activity and fibrosis (Actitest-Fibrotest) and liver biopsy in patients with chronic hepatitis C. Gastroenterol Clin Biol. Oct. 2008;32(10):858-65. [pmid: 18775614].
30 Fouad SA, Esmat S, Omran D, et al. Noninvasive assessment of hepatic fibrosis in Egyptian patients with chronic hepatitis C virus infection. World J Gastroenterol. Jun. 21. 2012;18(23):2988-94. [pmid: 22736923].
31 Friedrich-Rust M, Rosenberg W, Parkes J, et al. Comparison of ELF, FibroTest and FibroScan for the non-invasive assessment of liver fibrosis. BMC Gastroenterology. 2010;10(1):103. [pmid: 20828377].
32 Gabrielli GB, Capra F, Casaril M, et al. Serum laminin and type III procollagen in chronic hepatitis C. Diagnostic value in the assessment of disease activity and fibrosis. Clin Chim Acta. 1997;265(1):21-31. [pmid: 9352126].
33 Gara N, Zhao X, Kleiner DE, et al. Discordance Among Transient Elastography, Aspartate Aminotransferase to Platelet Ratio Index, and Histologic Assessments of Liver Fibrosis in Patients With Chronic Hepatitis C. Clin Gastroenterol Hepatol. Mar. 2013;11(3):303-8. Epub 2012 Nov 7. [pmid: 23142332].
34 Giannini (b) E, Testa R. Noninvasive diagnosis of fibrosis: The truth is rarely pure and never simple. Hepatology. 2003;38(5):1312-3. [pmid: 14578874].
35 Grigorescu M, Rusu M, Neculoiu D, et al. The FibroTest value in discriminating between insignificant and significant fibrosis in chronic hepatitis C patients. The Romanian experience. J Gastrointestin Liver Dis. 2007;16(1):31-7. [pmid: 17410286].
36 Guechot J, Trocme C, Renversez JC, et al. Independent validation of the Enhanced Liver Fibrosis (ELF) score in the ANRS HC EP 23 Fibrostar cohort of patients with chronic hepatitis C. Clinical Chemistry & Laboratory Medicine. Apr. 2012;50(4):693-9. [pmid: 22505560].
37 Halfon P, Bacq Y, De Muret A, et al. Comparison of test performance profile for blood tests of liver fibrosis in chronic hepatitis C. J Hepatol. 2007;46:395-402. [pmid: 17156890].
38 Halfon P, Penaranda G, Renou C, et al. External validation of FibroIndex. Hepatology. Jul. 2007;46(1):280-1. author reply 1-2. [pmid: 17596884].
39 Hsieh YY, Tung SY, Lee K, et al. Routine blood tests to predict liver fibrosis in chronic hepatitis C. World J Gastroenterol. Feb. 28. 2012;18(8):746-53. [pmid: 22371634].
40 Iacobellis A, Fusilli S, Mangia A, et al. Ultrasonographic and biochemical parameters in the non-invasive evaluation of liver fibrosis in hepatitis C virus chronic hepatitis. Aliment Pharmacol Ther. 2005;22(9):769-74. [pmid: 16225484].
41 Iacobellis A, Mangia A, Leandro G, et al. External validation of biochemical indices for noninvasive evaluation of liver fibrosis in HCV chronic hepatitis. Am J Gastroenterol. 2005;100(4):868-73. [pmid: 15784034].
42 Ichino N, Osakabe K, Nishikawa T, et al. A new index for non-invasive assessment of liver fibrosis. World J Gastroenterol. 2010;16(38):4809-16. [pmid: 20939109].
43 Imbert-Bismut F, Ratziu V, Pieroni L, et al. Biochemical markers of liver fibrosis in patients with hepatitis C virus infection: a prospective study. The Lancet. 2001;357(9262):1069-75. [pmid: 11297957].
44 Islam S, Antonsson L, Westin J, et al. Cirrhosis in hepatitis C virus-infected patients can be excluded using an index of standard biochemical serum markers. Scand J Gastroenterol. 2005;40(7):867-72. [pmid: 16109665].
45 Lackner C, Struber G, Liegl B, et al. Comparison and validation of simple noninvasive tests for prediction of fibrosis in chronic hepatitis C. Hepatology. 2005;41(6):1376-82. [pmid: 15915455].
46 Leroy V, Monier F, Bottari S, et al. Circulating matrix metalloproteinases 1, 2, 9 and their inhibitors TIMP-1 and TIMP-2 as serum markers of liver fibrosis in patients with chronic hepatitis C: comparison with PIIINP and hyaluronic acid. Am J Gast. 2004;99(2):271-9. [pmid: 15046217].
47 Loaeza-del-Castillo A, Paz-Pineda F, Oviedo-Cárdenas E, et al. AST to platelet ratio index (APRI) for the noninvasive evaluation of liver fibrosis. Ann Hepatol. 2008;7(4):350-7. [pmid: 19034235].
48 Lu SN, Wang JH, Liu SL, et al. Thrombocytopenia as a surrogate for cirrhosis and a marker for the identification of patients at high-risk for hepatocellular carcinoma. Cancer. Nov. 1. 2006;107(9):2212-22. [pmid: 17019738].
49 Martinez SM, Fernández-Varo G, González P, et al. Assessment of liver fibrosis before and after antiviral therapy by different serum marker panels in patients with chronic hepatitis C. Aliment Pharmacol Ther. 2011;33(1):138-48. [pmid: 21083589].
50 Morali G, Maor Y, Klar R, et al. Fibrotest-Actitest: the biochemical marker of liver fibrosis--the Israeli experience. Isr Med Assoc J. 2007;9:588-91. [pmid: 17877064].
51 Morra R, Munteanu M, Bedossa P, et al. Diagnostic value of serum protein profiling by SELDI-TOF ProteinChip compared with a biochemical marker, FibroTest, for the diagnosis of advanced fibrosis in patients with chronic hepatitis C. Aliment Pharmacol Ther. Sep. 15. 2007;26(6):847-58. [pmid: 17767469].
52 Mossong J, Bill S, Hawotte K, et al. Predicting significant fibrosis in hepatitis C patients in Luxembourg using serological markers. Bull Soc Sci Med Grand Duche Luxemb. 2011;(1):19-30. [pmid: 21634219].
53 Omran MM, Farid K, Emran TM, et al. Fibro-(alpha) score as a simple and useful non-invasive test for predicting significant liver fibrosis in chronic hepatitis C patients. Arab J Gastroenterol. 2011;12(2):74-9. [pmid: 21684477].
54 Parise ER, Oliveira AC, Figueiredo-Mendes C, et al. Noninvasive serum markers in the diagnosis of structural liver damage in chronic hepatitis C virus infection. Liver Int. 2006;26(9):1095-9. [pmid: 17032410].
55 Park JJ, Park JY, Kim do Y, et al. Prediction of significant fibrosis in chronic hepatitis C patients with normal ALT. Hepatogastroenterology. Jul-Aug. 2011;58(109):1321-7. [pmid: 21937403].
56 Park SH, Kim CH, Kim DJ, et al. Diagnostic value of multiple biomarker panel for prediction of significant fibrosis in chronic hepatitis C. Clin Biochem. 2011;44(17-18):1396-9. [pmid: 21971609].
57 Parkes J, Guha I, Roderick P, et al. Enhanced Liver Fibrosis (ELF) test accurately identifies liver fibrosis in patients with chronic hepatitis C. J Viral Hepatitis. 2010;18(1):23-31. [pmid: 20196799].
58 Patel K, Benhamou Y, Yoshida EM, et al. An independent and prospective comparison of two commercial fibrosis marker panels (HCV FibroSURE and FIBROSpect II) during albinterferon alfa-2b combination therapy for chronic hepatitis C. J Vir Hep. 2009;16(3):178-86. [pmid: 19175870].
59 Poynard T, Imbert-Bismut F, Ratziu V, et al. Biochemical markers of liver fibrosis in patients infected by hepatitis C virus: longitudinal validation in a randomized trial. J Vir Hep. 2002;9(2):128-33. [pmid: 11876795].
60 Poynard T, McHutchison J, Manns M, et al. Biochemical surrogate markers of liver fibrosis and activity in a randomized trial of peginterferon alfa-2b and ribavirin. Hepatology. 2003;38(2):481-92. [pmid: 12883493].
61 Rosenberg WM, Voelker M, Thiel R, et al. Serum markers detect the presence of liver fibrosis: a cohort study. Gastroenterology. 2004;127(6):1704-13. [pmid: 15578508].
62 Saitou Y, Shiraki K, Yamanaka Y, et al. Noninvasive estimation of liver fibrosis and response to interferon therapy by a serum fibrogenesis marker, YKL-40, in patients with HCV-associated liver disease. World J Gastroenterol. 2005;11(4):476-81. [pmid: 15641129].
63 Schneider AR, Teuber G, Kriener S, et al. Noninvasive assessment of liver steatosis, fibrosis and inflammation in chronic hepatitis C virus infection. Liver Int. 2005;25(6):1150-5. [pmid: 16343065].
64 Schneider AR, Teuber G, Paul K, et al. Patient age is a strong independent predictor of 13C-aminopyrine breath test results: a comparative study with histology, duplex-Doppler and a laboratory index in patients with chronic hepatitis C virus infection. Clin Exp Pharmacol Physiol. 2006;33(4):300-4. [pmid: 16620291].
65 Sebastiani G, Castera L, Halfon P, et al. The impact of liver disease aetiology and the stages of hepatic fibrosis on the performance of non-invasive fibrosis biomarkers: an international study of 2411 cases. Aliment Pharmacol Ther. 2011;34(10):1202-16. [pmid: 21981787].
66 Sebastiani G, Halfon P, Castera L, et al. Comparison of three algorithms of non-invasive markers of fibrosis in chronic hepatitis C. Aliment Pharmacol Ther. 2012;35(1):92-104. [pmid: 22035045].
67 Sebastiani G, Vario A, Guido M, et al. Performance of noninvasive markers for liver fibrosis is reduced in chronic hepatitis C with normal transaminases. J Vir Hep. 2008;15(3):212-8. [pmid: 18179453].
68 Sirli R, Sporea I, Bota S, et al. A comparative study of non-invasive methods for fibrosis assessment in chronic HCV infection. Hepat Mon. 2010;10(2):88-94. [pmid: 22312379].
69 Snyder N, Gajula L, Xiao SY, et al. APRI: An easy and validated predictor of hepatic fibrosis in chronic hepatitis C. J Clin Gastroenterol. 2006;40(6):535-42. [pmid: 16825937].
70 Snyder N, Nguyen A, Gajula L, et al. The APRI may be enhanced by the use of the FIBROSpect II in the estimation of fibrosis in chronic hepatitis C. Clinica Chimica Acta. 2007;381(2):119-23. [pmid: 17442291].
71 Stibbe KJM, Verveer C, Francke J, et al. Comparison of non-invasive assessment to diagnose liver fibrosis in chronic hepatitis B and C patients. Scand J Gastroenterol. Jul. 2011;46(7-8):962-72. [pmid: 21623677].
72 Testa R, Testa E, Giannini E, et al. Noninvasive ratio indexes to evaluate fibrosis staging in chronic hepatitis C: role of platelet count/spleen diameter ratio index. J Int Med. 2006;260(2):142-50. [pmid: 16882278].
73 Viana MSVB. Use of AST platelet ratio index (APRI Score) as an alternative to liver biopsy for treatment indication in chronic hepatitis C. Ann Hepatol. 2009;8(1). [pmid: 19221530].
74 Westin J, Ydreborg M, Islam S, et al. A non-invasive fibrosis score predicts treatment outcome in chronic hepatitis C infection. Scand J Gastroenterol. 2008;43:78-80.
75 Wilson LE, Torbenson M, Astemborski J, et al. Progression of liver fibrosis among injection drug users with chronic hepatitis C. Hepatology. 2006;43(4):788-95. [pmid: 16557548].
76 Yilmaz Y, Yonal O, Kurt R, et al. Noninvasive assessment of liver fibrosis with the aspartate transaminase to platelet ratio index (APRI): usefulness in patients with chronic liver disease. Hepat Mon. 2011;11(2):103-7. [pmid: 22087126].
77 Zarski JP, Sturm N, Guechot J, et al. Comparison of nine blood tests and transient elastography for liver fibrosis in chronic hepatitis C: the ANRS HCEP-23 study. J Hepatol. Jan. 2012;56(1):55-62. [pmid: 21781944].