# Abbreviations and Acronyms

API: age platelet index
APRI: aminotransferase/platelet ratio
AST: aspartate aminotransferase
AUROC: Area Under the Receiver Operating Characteristic
ELF: Enhanced Liver Fibrosis
METAVIR: Meta-analysis of Histological Data in Viral Hepatitis