# Summary and Discussion

## Summary

In this report we explored associations between a set of quality criteria and reported effect sizes in treatment effect trials, and explored factors influencing the presence and detection of associations in meta-epidemiological datasets.

In an analyzed empirical dataset, associations between quality and effect sizes were small, e.g., the ROR between unconcealed and concealed trials was 0.89 (95% CI: 0.73, 1.09; “Heterogeneity set”) but was overall consistent across the CBRG criteria. Based on a quantitative summary score, a cut-off of six or more criteria met (out of 11) differentiated low- and high-quality trials best in three out of four datasets (e.g., ROR 0.86, 95% CI: 0.70, 1.06; “Heterogeneity set”) but the effect was small and not statistically significant. Results for evidence of bias varied between meta-epidemiological datasets, individual meta-analyses within datasets, and clinical fields. Across all four datasets, most consistent associations between quality and effect sizes were found for allocation concealment with concealed trials showing smaller treatment effects.

Observed heterogeneity between studies varied across meta-epidemiological datasets. In an exploratory analysis, one dataset suggested a correlation between the effect size distribution and observed associations between quality and effect sizes; however, the effect could not be replicated in a second dataset.

The simulations showed that the power to detect quality effects is to a large extent determined by the degree of residual heterogeneity present in the dataset. Even large quality effects in simulations set up to maximize statistical power could not be detected in the presence of a large amount of additional heterogeneity across trials, that is, heterogeneity not due to quality.

### Observed Quality Effects

We set out to explore whether the proposed extended list of quality criteria is useful in different clinical fields (key question 1). Validating criteria and scales used to assess the quality of trials is challenging. The concept of quality is not easy to define, and there is no widely accepted gold standard. In addition, while the conceptual, underlying quality domains may be critical dimensions in the evaluation of trials, the applied quality criteria are a translation of the theoretical concepts. The theoretical concept is not identical with the applied test or measure, here the operationalization of the concept as individual quality criteria with scoring instructions for reviewers. The operationalization may or may not be successful and the validity of each operationalization needs to be assessed. We have previously reported evidence of convergent validity for the CBRG criteria (Hempel et al., 2011), based on the Jadad items and scale and the criteria suggested by Schulz et al. (1995) that we applied in parallel. However, evidence of bias would represent predictive validity – is meeting or not meeting the quality criteria associated with differential effect sizes?

To judge the quality of published studies, we depend on the features the authors chose to report in publications. The information depends in part on space restrictions of journals as well as changing reporting standards. The datasets we employed consisted of trials published over a long time period. Concerted efforts have been made to improve and standardize the reporting of empirical studies, particularly RCTs, resulting in the widely accepted Consort Statement, first published in 1996 (Begg et al., 1996). Generally, the quality of reporting has improved since the publication of the Consort statement (Kane, Wang & Garrard, 2007), and we, too, were able to show a significant trend in this direction in previously analyzed datasets (Hempel et al., 2011). The dataset assembled for this report was based on older meta-analyses and trials published earlier than previously analyzed datasets and is therefore particularly likely to suffer from a lack of reporting rather than lack of quality in the trial design or execution. In accordance with other investigations of quality effects (e.g., Hartling, Ospina, Liang, et al., 2009), we compared studies where criteria were reported as having been met with studies where the quality feature was not reported as having been met. We were concerned primarily with demonstrating the effects of high-quality studies; studies that reported a feature and the expression of the feature were an indicator of high quality. The publication year may have been a confounding factor in our analyses.

Similar to results reported by Balk et al. (2002), none of the individual quality criteria assessed in a meta-epidemiological dataset that was a replication of part of their dataset was associated with a statistically significant difference in effect sizes between trials meeting and trials not meeting the quality criteria. Balk and colleagues concluded from this (and the lack of consistency across clinical areas) that individual quality criteria are not reliably associated with reported treatment effect sizes. In our meta-epidemiological datasets we found that for CBRG criteria associations between quality and effect sizes were small; for example, the ROR between unconcealed and concealed trials was 0.89 (95% CI: 0.73, 1.09; “Heterogeneity set”) and not statistically significant but there seemed to be evidence of consistency across the CBRG criteria, indicating that low quality trials tended to overestimate treatment effects. We also found this trend across all four meta-epidemiological datasets, suggesting a non-random association between quality and effect sizes. In particular, concealed trials were consistently associated with smaller treatment effects in each of the four datasets.

We investigated the effects of individual quality criteria as well as a quantitative summary score and explored different cut-offs and their ability to differentiate between low- and high-quality studies (shown as differences in reported effect sizes between trials meeting a number of quality criteria versus trials not meeting these). Based on a quantitative summary score derived from the individual CBRG criteria, a cut-off of six or more criteria met (out of 11) differentiated low- and high-quality trials best in three out of four datasets (e.g., ROR 0.86, 95% CI: 0.70, 1.06; “Heterogeneity set”) suggesting an association between quality and effect sizes. However, this difference in effect size differences was only statistically significant in one out of four datasets, in the Back pain dataset for which clinical area the criteria were originally designed (see van Tulder et al., 2009).

Results for evidence of bias varied between meta-epidemiological datasets, broad clinical fields, and individual meta-analyses within datasets. All four meta-epidemiological datasets were derived from different meta-analyses representing diverse clinical fields. In addition, all included trials were selected based on their inclusion in specific meta-analyses rather than randomly selected from a pool of trials. Sterne et al. (2002) describe methods to allow for clustering on meta-analyses within a meta-epidemiological dataset, and we investigated the effects of clustering by contrasting the corrected and uncorrected standard errors between quality and effect sizes. In our analyses, the correction had no noticeable effect on estimates of the associations between quality and effect sizes. The use of the sandwich estimator is appropriate when any correlation of effect sizes within studies is considered to be a nuisance to be accounted for. Two alternative approaches were considered, a three-level meta-analysis, in which a multilevel modeling framework is used to account for clustering of studies, or a two stage meta-analysis, in which groups of studies are meta-analyzed and a meta-analysis of those results is carried out. The distribution of quality criteria across meta-analyses within each dataset was unbalanced—sometimes extremely so—hence the multilevel or the three level approach would absorb any quality effects into the random intercept.

While results clearly showed some variation between meta-epidemiological datasets, clinical fields, and meta-analyses, we also found that aggregating from individual criteria to summary scores resulted in less variation across the two broad clinical fields, pediatrics and cardiovascular disease, assessed as part of the “Heterogeneity” meta-epidemiological dataset. The use of checklists of individual criteria when scoring quality versus the application of a quantitative summary score has been extensively discussed in the literature. Juni and colleagues (Juni, Witschi, Bloch, et al., 1999; Juni, Altman, et al., 2001) raised serious concerns about the use of quantitative summary scores. However, treating all quality items as truly independent variables also does not appear appropriate, as outlined in Hempel et al. (2011). Individual CBRG quality items showed substantial inter-item correlations.

The equal weighting of each item as applied in our summary score approach is commonplace but has not been validated. Depending on the intervention and the clinical field, some internal validity threats may be more pertinent than others; however, there are as yet no data to guide what these associations may be. Individual quality criteria could be used to trigger an overall assessment of quality, which is more qualitatively than quantitatively derived, by adding individual item scores. The Cochrane review handbook currently suggests the use of a domain-based evaluation of quality, in which critical assessments are made separately for different domains (Higgins & Green, 2009). However, the reliability of qualitative overall evaluations has to be questioned, as Hartling et al. (2009) reported a kappa of 0.27 for reviewers to agree on the Cochrane Overall Risk of Bias dimension (Higgins & Green, 2008). Instead, a combined qualitative and quantitative approach might be useful: quality features could be ranked by importance for the clinical field a priori and weighted accordingly for a summary score.

Based on results shown in this report, it cannot be determined whether the proposed extended list of quality criteria should be applied regularly when judging the quality of studies. Individual criteria point to a uniform trend, but no statistically significant effect of quality on effect sizes was seen for any of the individual criteria. Based on a summary score that takes all 11 items into account, the largest difference in effect sizes was seen when applying a cut-off of six or more quality criteria met. However, the difference of combined measure did only marginally exceed those of individually criteria and statistically significant results were not shown in this dataset either. In order to evaluate this result, it is important to know the quality of the applied test as outlined in the section that follows on the detection of quality effects.

### Detection of Quality Effects

We used Monte Carlo simulations to systematically investigate the factors that influence the power to detect quality effects (key question 2). In these simulations, we set the effect of quality to a particular level and investigated its influence on the power to detect these effects. Monte Carlo simulations have been used to investigate the properties of meta-analysis parameter estimates under different conditions (e.g. Field, 2001; Field, 2005; Morton et al., 2004). No other studies have investigated (to our knowledge) the power to detect quality effects (or other study level moderators) under varying levels of study heterogeneity. In the simulations presented here, we investigated the effect of unexplained heterogeneity on the power to detect moderator effects of study quality.

In these simulations, power to detect quality moderator effects in the three datasets was variable. The simulations were set up to maximize the power. It should be noted that we assumed a best-case scenario by assigning 50 percent of studies to high quality and 50 percent to low quality. If this ratio were to move away from 50 percent, as is typical for empirical datasets, power would be reduced further. Furthermore, given the effect size for the main effect of the studies of approximately 0.5, a quality moderator effect of 0.2 means that the size of the effect would be overestimated by 60 percent in low quality studies. Yet even this large amount of bias due to quality proved difficult to detect in some of the analyses. We found that unexplained heterogeneity, at the levels estimated in our three datasets, dramatically reduced the power to detect a quality effect. The simulations therefore revealed that the estimates of the quality effects that failed to achieve significance are to be expected, even when quality effects are large relative to the size of the treatment effect. Where we also simulated datasets with reduced heterogeneity, we found improvements in power. Power can be increased through greater consistency of effect sizes between trials, a larger number of trials, larger trials, or larger effects of quality than are typically found in individual meta-analyses and some meta-epidemiological datasets.

While little research has directly examined the effects of heterogeneity on power in meta-analysis, there is a larger literature on the equivalent problem in cluster randomized trials, which are frequently analyzed with random effects multilevel models (Murray, 1998; Hayes and Moulton, 2010). In cluster randomized trials, the intra-class correlation describes the degree of similarity of patients within a cluster, relative to patients between clusters. In meta-analysis, patients are nested within trials, so heterogeneity means that patients within a trial are more closely related to patients in other trials than to each other.

The reported results provide assistance in interpreting the differences in results for associations between quality and effect sizes observed in previous datasets, documented in this and a previous report (Hempel et al., 2011). The results will also assist in planning future studies as outlined in the future research section.

### Causes and Implications of Heterogeneity

The simulation results may appear confusing with regards to heterogeneity. Trial quality is typically assessed as one source of heterogeneity. However, the simulations show that heterogeneity can also hinder the detection of quality effects. Quality effects can be a source of heterogeneity across trial results; however, unexplained heterogeneity (that is heterogeneity not due to quality effects), dramatically reduces the power to detect a quality effect. It is therefore useful to carefully examine the causes and implications of heterogeneity.

Although meta-analyses deal with heterogeneity in a variety of ways (Schroll et al, 2011), meta-regressions or subgroup analyses are conducted to explore whether differences in trial quality explain differences in reported trial results. However, the causes and implications of heterogeneity can be confused. If studies are considered to be samples from distinct populations – for example, of high and low quality, this will necessarily introduce a degree of heterogeneity. For example, when the studies are homogenous, the distribution of effect sizes is expected to follow a normal distribution, as shown in the figure (Figure 12). We have deliberately chosen a large effect size in the following examples to illustrate the causes and implications of heterogeneity.

Figure 12 Distribution of effect sizes where pooled effect size = 0.5

Figure 12 shows an effect size distribution where the effect size is set at 0.5; it is normally distributed.

Where there are two populations (for example, trials with and without blinding) there will be two overlapping distributions. The following figure (Figure 13) shows two populations of trials in which one population (solid line) has an effect size = 0.5, the second population has an effect size of 0.0. In this chart, there is a clear separation of the two populations, and this is therefore a source of heterogeneity.

Figure 13 Distributions of effect sizes from two populations where pooled effect sizes are = 0.5 – (solid line) and 0 (dashed line)

Figure 13 displays two effect size distributions, where pooled effect sizes are 0.5 and 0. Both are normally distributed but are parallel to each other.

The sum of the two distributions gives a mixture of distributions, as shown in the next figure (Figure 14), where (because the sample sizes were equal) there is a pooled estimate of the effect of 0.25.

Figure 14 Mixture of distributions from two populations, effect size = 0 and effect size = 0.5

Figure 14 shows a mixture of two populations of which one has an effect size equal to 0 and the other one equal to 0.5. This mixed distribution has heavier tails than the normal distributions shown in the previous figures.

This distribution shown in this figure has heavier tails and is wider and flatter than a normal distribution shown in the previous figures, although it is unlikely that this would be detectable in practice. However, the variance of the distribution of this pooled sample is larger than would be expected which would signal that there was heterogeneity which could be explored.

When additional sources of heterogeneity are also present, in addition to heterogeneity due to the quality of studies, the heterogeneity is harder to discern; both by eye, and statistically. In the following figure (Figure 15), we have increased the degree of heterogeneity (the standard deviation is doubled), whilst maintaining the difference between effect sizes (at 0.5). This has the effect of halving the relative effect size, and thereby reducing the power to detect a difference between the two populations.

Figure 15 Difference between effect sizes of 0.5 with SD of effect sizes equal to 2

Figure 15 shows the difference between two populations where we have increased the degree of heterogeneity (so that the standard deviation is doubled), whilst maintaining the difference between effect sizes (at 0.5). When additional sources of heterogeneity are present, heterogeneity is harder to discern; both by eye, and statistically.

As shown in the figure, heterogeneity has therefore increased the difficulty of detecting the difference between high and low quality studies.

In our empirical data, a comparison between meta-epidemiological datasets showed that observed heterogeneity between trials within the meta-epidemiological datasets varied across datasets. In an exploratory analysis we attempted to correlate distribution (shape) characteristics and the strength of associations between quality and effect sizes but results were inconclusive. Quality effects are one source of heterogeneity which can be accounted for in the meta-analysis; however there are a very wide range of other factors that can introduce heterogeneity which are not quantified in the published papers, and the effects of which may be impossible to quantify. For example, in a study investigating quality effects in a diverse set of studies such as this, the effectiveness of the intervention and the sensitivity of the outcome may vary across trials. Even if these factors were accounted for, heterogeneity may still exist, Glasziou and Sanders (2002) discussed factors which cause heterogeneity, and suggested that they included features of the population such as age, severity of illness, gender, intervention factors (does, timing, duration of treatment) and co-interventions.

## Limitations

As outlined, we tested a specific set of quality criteria and our conclusions for individual quality criteria are specific to the applied operationalization. The criteria tried to capture conceptual quality domains; however, we only have empirical data on the applied quality criteria scored by individual reviewers, the translation of the theoretical concepts.

For the current analyses we set out to use different meta-epidemiological datasets with known qualities. For the two published datasets that were selected (Moher et al., 1998; Balk et al., 2001) we tried to closely match study selections and analytical results. However, since the publications reported only limited detail, the replication was close but not identical. In addition, different quality measures and scoring interpretations were used to assess the quality of trials.

The different datasets were compiled for unique reasons and selection criteria. Among the four datasets, dataset 2 (the EPC report sample) showed the most unusual results for all included quality assessment instruments, CBRG criteria and others. In particular, the exploration of the effect size distribution points to the dataset as an outlier compared to the other compiled datasets. Most notable were the skewed distribution and extreme differences in effect sizes across conditions, as previously discussed (Hempel et al., 2011). This sample was a convenience sample based on availability of data. In addition, the included meta-analyses may have been too diverse with regard to clinical fields, interventions, and outcomes, which, in turn, may have introduced too many significant confounders to be useful for analyzing the research question.

The data showed that a cut-off of six or more criteria met (out of 11) differentiated low- and high-quality trials best (ROR 0.86, 95% CI: 0.70, 1.06), however, the difference between study groups was not statistically significant and two other cut-offs were only marginally different in their performance (cut-off at 7 and 8 criteria met showed a ROR or 0.88).

We did not assess the inter-rater reliability as part of this project, but other reliability measures have been reported in a previous report (Hempel et al., 2011). The reproducibility of quality judgments across independent raters is a valuable method for estimating the reliability of proposed items, but for evidence reviews it is standard to reconcile independent rater decisions. This approach helps to avoid individual reviewer bias and errors and the reconciled decision should be more reliable than the individual decision. Testing the rater agreement of reconciled decisions requires more than one pair of raters.

Detecting and interpreting quality effects are hampered by the observational nature of the data that are available to researchers. When studies differ by quality, it is likely that they differ in other ways as well, both measured and unmeasured, which also might affect the effect size found in the study. For example, it may be the case that researchers running trials that are better funded are likely to carry out blinding more effectively, which may reduce effect sizes. However, these same researchers may have the resources to pay attention to treatment fidelity, which may improve effect sizes, and increase the effect size.

All of the presented analyses were exploratory in nature. The research field is developing, there are no established standards, and many open questions remain. Consequently, we have formulated cautious conclusions.

## Future Research

Our analyses have shown that it is challenging for individual meta-analyses to detect effects of study quality on reported treatment effects. The modeling results showed that under most circumstances it is difficult to detect a quality effect, even when it is present and even when it is substantial. Although they included hundreds of individual trials, the datasets we have compiled in the course of the project did not necessarily have the power to detect influences of quality on effect sizes. From this observation, it follows that the failure to detect a statistically significant quality effect should not be interpreted as meaning that a quality effect is not present.

Future studies that investigate the effects of quality as a moderator of outcome in randomized controlled trials should take steps to ensure that unexplained heterogeneity, that is heterogeneity unrelated to potential quality effects, is minimized. In meta-epidemiological studies, power to detect quality effects can be increased through greater consistency of effect sizes between trials, possibly the careful selection of research areas, or a larger number of trials or larger trials. Theoretically, power would increase as well with larger effects of quality, larger effects than are typically found in individual meta-analyses and some meta-epidemiological datasets. Selection of trials to be incorporated into analyses may allow researchers to construct datasets that maximize power to detect quality effects. This may be done by careful selection of meta-analyses which incorporate both balance in covariates; that is,, with approximately equal numbers of high- and low-quality studies, and without excessive heterogeneity. Power analyses may then be carried out to determine whether the selected studies are likely to have power to detect quality effects.

Recent methodological advances have allowed researchers to make stronger causal conclusions from correlational or observational data. One approach that we believe may be fruitful is the use of propensity based matching (Pearl, 2009; Guo & Fraser, 2010; Rosenbaum & Rubin, 1983; Rosenbaum & Rubin, 1984), in which samples are selected and matched based on observed differences in the variables of interest.

As outlined, failure to detect a statistically significant quality effect should not be interpreted as meaning that a quality effect is not present in individual meta-analyses. Furthermore, based on our analyses, individual meta-analyses should include steps to minimize heterogeneity through the inclusion of additional study level covariates. These refinements can reduce unexplained heterogeneity and thereby aid the investigation of quality effects and the potential for bias.

More empirical evidence is needed to determine which quality features are likely to influence reported effect sizes, and under which conditions. This question is of particular importance for the critical appraisal of systematic reviews when aiming to summarize the existing evidence appropriately. Datasets and quality assessments assembled for the course of this project provide a wealth of information and may assist in answering remaining questions in this developing research field. In addition, the Bias in Randomized and Observational Studies (BRANDO) dataset, with 3,477 trials, may prove to be useful for future meta-epidemiological analyses (see Savovic et al., 2010).

## Conclusion

Although trial quality may explain some amount of heterogeneity across trial results in meta-analyses, the amount of additional heterogeneity (not due to trial quality) in effect sizes is a crucial factor determining when associations between quality and effect sizes can be detected. Detecting quality moderator effects requires more statistically powerful analyses than are employed in many investigations.