# Results

This section describes the empirical datasets and the observed association between quality and effect sizes, the heterogeneity and effect size distribution represented in the datasets, and the Monte Carlo simulation results. Throughout, the different dataset results are compared and similarities and differences are highlighted.

## Empirical Datasets

Three of the datasets (Back pain, EPC reports, ‘Pro-bias’) we used for our analyses have been described in detail elsewhere (Hempel et al., 2011). As outlined, we added an additional meta-epidemiological dataset to explore the associations between quality and effect sizes for the purpose of this study. Dataset 4 is henceforth called ‘Heterogeneity set,’ to indicate that this dataset comprised meta-analyses selected to show heterogeneity between studies.

### Dataset Description

Figure 3 shows the years of publication of the included papers for all four datasets.

Figure 3 Year of publication of included trials

EPC = Evidence Based Practice Center

Figure 3 is a line graph representing the years of publication of the included studies for all four datasets. It shows in particular that the fourth dataset (Heterogeneity set) includes older studies (some published in the 1940s) compared to the other three datasets.

The studies included in the new dataset ‘Heterogeneity set’ were older than those included in the Back pain, EPC reports and ‘Pro-bias’ datasets.

#### Quality of the Reporting

The figure below (Figure 4) shows the distribution of answers to the quality items (yes, unclear, no) for this new empirical dataset, “Heterogeneity set.” A “yes” is an indicator of high quality for each of the items (randomization sequence, allocation concealment, baseline similarity, outcome assessor blinding, care provider blinding, patient blinding, dropout rate and description, analysis in original group (ITT), co-interventions, compliance, and assessment timing); for example, that the outcome assessors were blinded.

Figure 4 Quality item answer distribution “Heterogeneity set”

ITT = intention to treat

Figure 4 shows a bar chart depicting the "yes," "no," and "unclear" answers given to the 11 quality criteria for the "Heterogeneity" dataset. The figure shows that in many cases there was not enough information to judge the quality of the study.

For many quality criteria, information was insufficient to judge the individual quality feature. Although the large majority of trials were described as randomized, many publications did not report on the generation of the randomization sequence and whether a truly random sequence was adhered to.

The figure below (Figure 5) allows a comparison of “yes” answers across the four datasets, i.e. an indication that the feature was reported in the publication and the criterion was met.

Figure 5 Criterion met across datasets

EPC = Evidence Based Practice Center; ITT = intention to treat

Figure 5 is a column graph that allows a comparison of "yes" answers across the four datasets to each of the 11 quality criteria. The distribution of yes answers is similar but not identical across the datasets and varies by quality item.

The distribution of treatment effects for all 149 trials included in the ‘Heterogeneity’ dataset is shown in figure below (Figure 6) (the log odds ratios are displayed).

Figure 6 Treatment effect distribution of “Heterogeneity set”

OR = odds ratio

Figure 6 is a histogram showing the distribution of treatment effects of all trials included in the 'Heterogeneity' dataset (log scale). The distribution resembles a normal distribution and is fairly symmetric.

### Observed Association Between Quality and Effect Sizes

As outlined in the methods section, we investigated whether there was an association between the quality of the trial and the reported treatment effect of the trial. The following tables show the odds ratios in trials meeting a quality criterion, the odds ratio of trials not meeting the criterion, and the ratio of odds ratios between these trial groups for the new dataset specifically compiled for this report (Dataset 4, ‘Heterogeneity set’). This set is based on a previously published datasets with known qualities as outlined in the methods section. In addition, the tables report the number of trials meeting each criterion and the number of trials not meeting the criterion, to demonstrate how common each quality aspect was in the sample and to show the sample size of trials in each group of trials (that is the number of low- and high-quality trials applying each respective quality criterion).

Table 2 Ratio of odds ratios between studies fulfilling criteria: “Heterogeneity set,” CBRG criteria

CBRG Criteria | # Criterion met | # Criterion not met | OR (met) | 95% CI (met) | OR (not met) | 95% CI (not met) | ROR | 95% CI
Randomization adequate | 41 | 108 | 0.65 | (0.53, 0.79) | 0.76 | (0.68, 0.86) | 1.18 | (0.94, 1.49)
Allocation concealment | 52 | 97 | 0.79 | (0.67, 0.92) | 0.70 | (0.61, 0.80) | 0.89 | (0.73, 1.09)
Similar baseline | 66 | 83 | 0.75 | (0.65, 0.86) | 0.71 | (0.62, 0.82) | 0.95 | (0.78, 1.16)
Assessor blind | 93 | 56 | 0.73 | (0.65, 0.83) | 0.73 | (0.62, 0.86) | 0.99 | (0.80, 1.22)
Care provider blind | 79 | 70 | 0.75 | (0.66, 0.86) | 0.71 | (0.61, 0.82) | 0.94 | (0.77, 1.15)
Patient blind | 93 | 56 | 0.77 | (0.68, 0.87) | 0.67 | (0.57, 0.80) | 0.88 | (0.71, 1.08)
Acceptable dropout rate | 107 | 42 | 0.73 | (0.65, 0.82) | 0.74 | (0.61, 0.90) | 1.02 | (0.81, 1.27)
Original group (ITT) | 73 | 76 | 0.76 | (0.66, 0.87) | 0.71 | (0.61, 0.82) | 0.93 | (0.76, 1.14)
Similar co-interventions | 71 | 78 | 0.80 | (0.69, 0.92) | 0.68 | (0.59, 0.78) | 0.85 | (0.69, 1.03)
Acceptable compliance | 109 | 40 | 0.71 | (0.63, 0.80) | 0.80 | (0.65, 0.98) | 1.12 | (0.89, 1.41)
Similar timing | 141 | 8 | 0.74 | (0.67, 0.82) | 0.64 | (0.43, 0.97) | 0.87 | (0.57, 1.32)
Summary Score
≥ 9 vs<9 | 25 | 124 | 0.77 | (0.61, 0.97) | 0.73 | (0.65, 0.81) | 0.94 | (0.73, 1.22)
≥ 8 vs <8 | 44 | 105 | 0.80 | (0.67, 0.96) | 0.71 | (0.63, 0.79) | 0.88 | (0.71, 1.09)
≥ 7 vs <7 | 72 | 77 | 0.78 | (0.68, 0.89) | 0.69 | (0.60, 0.79) | 0.88 | (0.72, 1.08)
≥ 6 vs <6 | 91 | 58 | 0.77 | (0.69, 0.87) | 0.66 | (0.56, 0.79) | 0.86 | (0.70, 1.06)
≥ 5 vs <5 | 114 | 35 | 0.73 | (0.66, 0.82) | 0.73 | (0.58, 0.92) | 1.00 | (0.77, 1.28)
≥ 4 vs <4 | 132 | 17 | 0.74 | (0.67, 0.82) | 0.66 | (0.46, 0.94) | 0.89 | (0.61, 1.29)

CBRG = Cochrane Back Review Group; CI = confidence interval, OR = odds ratio, ROR = ratio of odds ratios

The associations between the CBRG quality criteria and effect sizes were small and none achieved statistical significance in this dataset. For example, unconcealed compared to concealed trials showed an ROR of 0.89, 95% CI: 0.73, 1.09. However, the majority of RORs indicated that trials without meeting a quality criterion reported slightly larger treatment effects across investigated criteria (i.e. concealment of treatment allocation, similarity of baseline values, blinding of care providers, blinding of patients, intention-to-treat analysis, similarity of co-interventions, and similar timing of outcome assessment). In this dataset, adequate randomization and acceptable compliance were associated with larger effects, while acceptable dropout rates and assessor blinding did not show any or only extremely small differences in effect sizes.

Based on a quantitative summary score derived from all quality criteria, a cut-off of six or more criteria met differentiated low- and high-quality trials best with an ROR of 0.86 (95% CI: 0.70, 1.06).

The figure below (Figure 7) graphically represents the association between quality and effect sizes for the individual quality criteria in the “Heterogeneity” dataset.

Figure 7 Ratio of odds ratios between studies fulfilling CBRG criteria versus not: “Heterogeneity set”

CBRG = Cochrane Back Review Group; ROR = ratio of odds ratios

Figure 7 is a forest plot graphically representing the association between quality and effect sizes for the individual quality criteria. Apart from "three" items, lower quality studies reported consistently larger effect sizes.

The figure displays the ratio of odds ratios of reported effect sizes for low- and high-quality trials. In addition, the 95 percent confidence interval for the effect is shown.

For trials included in this fourth dataset we have also applied the Jadad scale, criteria suggested by Schulz et al. (1995), and the Cochrane risk of bias tool. Although all represented quality domains are also included in the 11-item CBRG quality criteria list, individual operationalizations vary slightly across measures. The table below (Table 3) shows the results for the individual Jadad criteria, the total Jadad score, the Schulz criteria, and the individual Risk of Bias tool criteria as well as the overall Cochrane risk of bias assessment.

Table 3 Ratio of odds ratios between studies fulfilling criteria; “Heterogeneity set,” other criteria

Quality Criteria | # Criterion met | # Criterion not met | OR (met) | 95% CI (met) | OR (not met) | 95% CI (not met) | ROR (met) | 95% CI (not met)
Jadad
Randomization=2 | 34 | 115 | 0.61 | (0.49, 0.76) | 0.77 | (0.69, 0.86) | 1.27 | (0.99, 1.62)
Blinding=2 | 41 | 108 | 0.76 | (0.63, 0.91) | 0.72 | (0.64, 0.81) | 0.95 | (0.76, 1.18)
Withdrawal=1 | 119 | 30 | 0.75 | (0.67, 0.84) | 0.68 | (0.54, 0.85) | 0.91 | (0.71, 1.17)
Jadad: total ≥3 | 83 | 66 | 0.70 | (0.61, 0.80) | 0.78 | (0.67, 0.91) | 1.11 | (0.90, 1.36)
Schulz
Concealment | 52 | 97 | 0.79 | (0.68, 0.92) | 0.70 | (0.61, 0.79) | 0.89 | (0.72, 1.08)
Sequence | 34 | 115 | 0.61 | (0.49, 0.76) | 0.77 | (0.69, 0.86) | 1.27 | (0.99, 1.62)
Analysis | 77 | 72 | 0.72 | (0.63, 0.83) | 0.74 | (0.64, 0.86) | 1.03 | (0.84, 1.26)
Blinding | 78 | 71 | 0.75 | (0.66, 0.87) | 0.71 | (0.61, 0.82) | 0.94 | (0.77, 1.15)
Cochrane Risk of Bias
Sequence generation | 35 | 114 | 0.60 | (0.48, 0.75) | 0.77 | (0.69, 0.86) | 1.28 | (1.00, 1.64)
Allocation concealment | 51 | 98 | 0.79 | (0.68, 0.93) | 0.69 | (0.61, 0.79) | 0.87 | (0.72, 1.07)
Blinding | 79 | 70 | 0.75 | (0.66, 0.86) | 0.71 | (0.61, 0.82) | 0.94 | (0.77, 1.15)
Incompl. outcome data | 74 | 75 | 0.75 | (0.65, 0.86) | 0.72 | (0.62, 0.83) | 0.96 | (0.78, 1.17)
Sel. outcome reporting | 123 | 26 | 0.75 | (0.67, 0.83) | 0.65 | (0.50, 0.84) | 0.86 | (0.65, 1.14)
Other sources of bias | 38 | 111 | 0.74 | (0.61, 0.89) | 0.73 | (0.65, 0.82) | 0.99 | (0.80, 1.24)
RoB overall risks | 43 | 106 | 0.76 | (0.62, 0.92) | 0.72 | (0.64, 0.81) | 0.96 | (0.76, 1.20)

CI = confidence interval; OR = odds ratio; RoB = risk of bias; ROR = ratio of odds ratios

Note: The Jadad randomization and blinding score ranges from 0 to 2, the withdrawal score from 0 to 1, the total score from 0 to 5.

Applying the Jadad criteria, higher quality studies reported slightly larger treatment effects, primarily triggered by the randomization item (“Was the study described as randomized and was the method to generate the sequence appropriate?”). Double-blinding and a description of withdrawals showed effects corresponding with the CBRG quality criteria (i.e., criteria met are associated with smaller reported effect sizes). The Schulz criteria showed similar results to the Jadad criteria, and allocation concealment showed the largest difference between low- and high-quality studies (0.89; 95% CI: 0.72, 1.08). The Cochrane risk of bias tool also showed small effects of quality, with lower quality studies reporting larger effect sizes; however the sequence generation item again showed the opposite effect. None of the effects are statistically significant.

#### Sensitivity Analyses: Stratification by Meta-analysis, Stratification by Clinical Area, and Correction for Clustering

In order to investigate whether the associations between quality and effect sizes are consistent or notably different across individual meta-analyses and clinical fields, we stratified the “Heterogeneity” dataset accordingly. As outlined previously, the dataset includes trials from 13 meta-analyses from two very different fields: pediatric interventions and cardiovascular disease interventions.

The table below (Table 4) shows the effect size difference expressed as the ratio of odds ratio for low (criterion not met) and high (criterion met) quality studies for each meta-analysis.

Table 4 Difference in odds ratios for studies fulfilling CBRG criteria by individual meta-analyses

CBRG Criteria | ROR (a) | ROR (b) | ROR (c) | ROR (d) | ROR (e) | ROR (f) | ROR (g) | ROR (h) | ROR (i) | ROR (j) | ROR (k) | ROR (l) | ROR (m)
Randomization adequate | NC | 0.35 | 1.99 | 0.83 | 2.09 | 1.13 | NC | 0.96 | NC | 0.88 | 1.39 | NC | 0.47
Allocation concealment | NC | 0.97 | NC | 1.69 | NC | 1.11 | 0.55 | 0.59 | 1.01 | 0.88 | 0.70 | 0.89 | 0.98
Similar baseline | NC | 0.97 | 1.33 | 0.85 | 0.55 | 0.82 | 1.13 | 0.83 | 1.07 | 1.00 | 0.49 | NC | 1.15
Assessor blind | NC | 1.00 | NC | 1.06 | 0.42 | 0.98 | 0.80 | 0.89 | NC | 1.07 | 0.65 | 0.74 | NC
Care provider blind | NC | NC | NC | 0.66 | 0.58 | 0.98 | 0.80 | 0.89 | NC | 1.60 | 0.67 | 0.76 | NC
Patient blind | NC | NC | NC | 0.66 | 0.58 | NC | NC | 0.71 | NC | 1.05 | 0.48 | 0.76 | NC
Acceptable dropout rate | NC | NC | 0.69 | 0.69 | 1.34 | 1.26 | 1.21 | 1.07 | 1.07 | 1.13 | 1.36 | NC | NC
Original group (ITT) | NC | 3.04 | 2.97 | 1.38 | 2.84 | 0.70 | 0.69 | NC | 0.80 | 1.11 | 0.81 | 1.41 | 1.47
Similar co-interventions | NC | 0.31 | NC | 0.78 | 0.72 | NC | 1.29 | 0.89 | 0.85 | 0.93 | NC | NC | 1.74
Acceptable compliance | NC | NC | NC | 1.25 | 2.02 | NC | 0.73 | 0.87 | 0.91 | NC | NC | NC | NC
Similar timing | NC | NC | NC | 0.64 | NC | 0.91 | NC | NC | NC | 0.83 | NC | NC | NC
Summary Score
≥9 vs<9 | NC | 0.73 | NC | NC | NC | 1.12 | 0.80 | NC | 1.08 | NC | NC | NC | 1.98
≥8 vs <8 | NC | 0.97 | 3.11 | 0.59 | NC | 0.86 | 0.80 | NC | 1.08 | 1.04 | NC | NC | 1.23
≥7 vs <7 | NC | NC | 0.69 | 0.53 | NC | 0.98 | 0.80 | 0.70 | 0.71 | 1.09 | 0.56 | 0.89 | NC
≥6 vs <6 | NC | NC | 0.69 | 0.60 | NC | NC | 0.80 | 0.89 | 0.72 | 1.10 | 0.27 | 1.07 | NC
≥5 vs <5 | NC | NC | NC | 0.97 | 0.97 | NC | NC | 0.86 | 0.72 | 0.99 | NC | NC | NC
≥4 vs <4 | NC | NC | NC | 1.94 | 0.77 | NC | NC | NC | NC | 0.75 | NC | NC | NC

ATC = Antiplatelet Trialists’ Collaboration; CBRG = Cochrane Back Review Group; ITT = intention to treat; NC = could not be computed (less than 3 trials in the high or low quality trial group); ROR = ratio of odds ratios

Note: [underlined: List of meta-analyses (see reference list)]: (a) Ausejo;(b) Bhuta; (c) Kellner; (d) Kozyrskyj; (e) Rosenfeld; (f) ATC; (g) Hine; (h) Leizorovicz; (i)Yusuf, beta-blockade; (j)Yusuf, streptokinase; (k) Yusuf, nitrates; (l) Rossouw; (m) Teo.

Note: An ROR less than 1 indicates that high-quality trials reported a smaller treatment effect compared to those trials that met the quality criteria.

The number of included trials varied across meta-analyses, and for several individual meta-analyses the ratio of odds ratio of high and low quality studies could not be calculated because there were fewer than three trials present in the group of high-quality trials and/or low-quality trials. In meta-analyses that included a sufficient number of trials, effects of quality varied, in terms of both size and direction of effects. Reported concealment of treatment allocation was associated with smaller treatment effects in seven individual meta-analyses. (The ratio of odds ratios ranged from 0.55 to 0.98.) In three meta-analyses the opposite effect was found, and in three meta-analyses the effect could not be studied due to the small number of included trials.

As mentioned, the individual meta-analyses represented two very different clinical fields. Five meta-analyses investigated interventions in pediatric samples. The remaining were cardiovascular disease meta-analyses. The table below (Table 5) shows the effect size difference for high (criterion fulfilled) and low (criterion not fulfilled) quality studies for each of the two general clinical fields.

Table 5 Difference in odds ratios for studies fulfilling CBRG criteria by clinical field

CBRG Criteria | ROR Pediatrics N=56 | 95% CI Pediatrics | ROR Cardiovascular Disease N=93 | 95% CI Cardiovascular Disease
Randomization adequate | 1.86 | (0.93, 3.70) | 1.02 | (0.85, 1.23)
Allocation concealment | 1.52 | (0.75, 3.07) | 0.85^*^ | (0.73, 0.99)^*^
Similar baseline | 1.15 | (0.61, 2.19) | 0.93 | (0.80, 1.09)
Assessor blind | 1.17 | (0.58, 2.37) | 0.91 | (0.77, 1.07)
Care provider blind | 0.98 | (0.51, 1.86) | 0.90 | (0.78, 1.05)
Patient blind | 0.98 | (0.51, 1.86) | 0.87 | (0.74, 1.03)
Acceptable dropout rate | 0.83 | (0.40, 1.72) | 1.12 | (0.95, 1.33)
Original group (ITT) | 1.45 | (0.75, 2.79) | 0.91 | (0.78, 1.07)
Similar co-interventions | 0.51^*^ | (0.28, 0.94)^*^ | 0.96 | (0.82, 1.11)
Acceptable compliance | 1.87 | (0.98, 3.57) | 0.99 | (0.81, 1.20)
Similar timing | 0.78 | (0.21, 2.94) | 0.81 | (0.56, 1.16)
Summary Score
≥9 vs< | 1.15 | (0.52, 2.59) | 0.93 | (0.76, 1.13)
≥8 vs < | 1.23 | (0.61, 2.49) | 0.84^*^ | (0.72, 0.98)^*^
≥7 vs < | 1.09 | (0.57, 2.10) | 0.91 | (0.78, 1.06)
≥6 vs < | 0.90 | (0.47, 1.70) | 0.95 | (0.79, 1.13)
≥5 vs < | 1.46 | (0.72, 2.93) | 0.88 | (0.71, 1.08)
≥4 vs < | 1.59 | (0.62, 4.08) | 0.71^*^ | (0.53, 0.94)^*^

CBRG = Cochrane Back Review Group; CI = confidence interval; ITT = intention to treat; ROR = ratio of odds ratios

* p<0.05

Note: An ROR less than 1 indicates that high-quality trials reported a smaller treatment effect compared to those trials that met the quality criteria.

Across clinical fields, the effects associated with individual quality criteria varied. Meeting quality criteria was sometimes associated with a smaller treatment effect and sometimes with a smaller reported effect. Based on a quantitative summary score, a cut-off of 6 quality criteria met was most consistent across clinical fields.

As a further sensitivity analysis we estimated meta-regressions correcting for clustering with meta-analysis using a Huber/White (sandwich) estimator. Table 6 presents corrected and uncorrected point estimates and confidence intervals.

Table 6 Ratio of odds ratios for CBRG criteria corrected and uncorrected for clustering

CBRG Criteria | ROR | 95% CI | ROR (Corrected) | 95% CI (Corrected)
Randomization adequate | 1.18 | (0.94, 1.49) | 1.18 | (0.83, 1.67)
Allocation concealment | 0.89 | (0.73, 1.09) | 0.89 | (0.66, 1.18)
Similar baseline | 0.95 | (0.78, 1.16) | 0.95 | (0.78, 1.17)
Assessor blind | 0.99 | (0.80, 1.22) | 0.98 | (0.79, 1.22)
Care provider blind | 0.94 | (0.77, 1.15) | 0.94 | (0.78, 1.13)
Patient blind | 0.88 | (0.71, 1.08) | 0.88 | (0.69, 1.12)
Acceptable dropout rate | 1.02 | (0.81, 1.27) | 1.13 | (0.84, 1.51)
Original group (ITT) | 0.93 | (0.76, 1.14) | 0.92 | (0.68, 1.26)
Similar co-interventions | 0.85 | (0.69, 1.03) | 0.86 | (0.73, 0.99)^*^
Acceptable compliance | 1.12 | (0.89, 1.41) | 1.10 | (0.83, 1.45)
Similar timing | 0.87 | (0.57, 1.32) | 0.85 | (0.67, 1.08)

CBRG = Cochrane Back Review Group; CI = confidence interval; ITT = intention to treat; ROR: ratio of odds ratios, corrected for clustering using a Huber/White (sandwich) estimator

* p<0.05

We found that this alternative estimation procedure made only small changes to estimates and standard errors and corresponding confidence intervals.

#### Comparison Across Meta-epidemiological Datasets

The following table (Table 7) compares the association between quality and effect sizes across the four epidemiological datasets that we compiled in the course of the project. The individual CBRG criteria are shown; in addition, the results for the quantitative summary score exploring different cut-offs are reported. Note the dataset 1 and 2 are displayed as effect size differences, for dataset 3 and 4 the ratio of odds ratio is shown.

Table 7 CBRG criteria across datasets

CBRG Criteria | Dataset 1 Back Pain | | Dataset 2 EPC Reports | | Dataset 3 Pro-bias | | Dataset 4 Heterogeneity set
CBRG Criteria | ESdiff | 95% CI | ESdiff | 95% CI | ROR | 95% CI | ROR | 95% CI
Randomization adequate | 0.02 | (-0.12, 0.16) | 0.01 | (-0.15, 0.17) | 0.94 | (0.75, 1.17) | 1.18 | (0.94, 1.49)
Allocation concealment | -0.08 | (-0.23, 0.07) | -0.05 | (-0.22, 0.11) | 0.91 | (0.72, 1.14) | 0.89 | (0.73, 1.09)
Similar baseline | -0.10 | (-0.24, 0.05) | -0.09 | (-0.24, 0.05) | 0.98 | (0.80, 1.21) | 0.95 | (0.78, 1.16)
Assessor blind | -0.10 | (-0.25, 0.04) | 0.06 | (-0.28, 0.41) | 1.35 | (1.05, 1.73) | 0.99 | (0.80, 1.22)
Care provider blind | -0.10 | (-0.26, 0.06) | 0.19 | (0.03, 0.35)^*^ | 0.83 | (0.67, 1.02) | 0.94 | (0.77, 1.15)
Patient blind | -0.03 | (-0.18, 0.11) | 0.21 | (0.04, 0.39)^*^ | 0.97 | (0.78, 1.21) | 0.88 | (0.71, 1.08)
Acceptable dropout | -0.13 | (-0.29, 0.02) | 0.15 | (0.01, 0.29)^*^ | 0.72 | (0.59, 0.88) | 1.02 | (0.81, 1.27)
Original group (ITT) | -0.10 | (-0.24, 0.04) | 0.05 | (-0.10, 0.20) | 0.91 | (0.74, 1.12) | 0.93 | (0.76, 1.14)
Similar co-interventions | -0.09 | (-0.23, 0.05) | 0.05 | (-0.15, 0.28) | 1.50 | (1.22, 1.85) | 0.85 | (0.69, 1.03)
Acceptable compliance | -0.01 | (-0.15, 0.14) | 0.02 | (-0.12, 0.17) | 0.72 | (0.59, 0.88) | 1.12 | (0.89, 1.41)
Similar timing | -0.17 | (-0.43, 0.10) | 0.25 | (-0.19, 0.69) | 1.33 | (0.94, 1.88) | 0.87 | (0.57, 1.32)
Summary Score
≥9 vs 9 | -0.04 | (-0.29, 0.20) | 0.15 | (-0.01, 0.30) | 1.09 | (0.81, 1.46) | 0.94 | (0.73, 1.22)
≥8 vs 8 | -0.09 | (-0.26, 0.08) | 0.03 | (-0.11, 0.18) | 0.85 | (0.68, 1.07) | 0.88 | (0.71, 1.09)
≥7 vs 7 | -0.10 | (-0.24, 0.05) | 0.01 | (-0.14, 0.16) | 1.05 | (0.86, 1.29) | 0.88 | (0.72, 1.08)
≥6 vs 6 | -0.20 | (-0.34, -0.06)^*^ | 0.16 | (-0.03, 0.35) | 0.77 | (0.63, 0.95)^*^ | 0.86 | (0.70, 1.06)
≥5 vs 5 | -0.20 | (-0.35, -0.05)^*^ | 0.27 | (0.02, 0.52)^*^ | 0.79 | (0.63, 0.99)^*^ | 1.00 | (0.77, 1.28)
≥4 vs 4 | -0.13 | (-0.31, 0.06) | 0.41 | (-0.02, 0.84) | 0.83 | (0.65, 1.07) | 0.89 | (0.61, 1.29)

CBRG = Cochrane Back Review Group; CI = confidence interval, ESdiff = effect size difference; ITT = intention to treat; ROR = ratio of odds ratios

* p<0.05

Note: “Pro-bias” data are based on fixed-effects model.

Observed associations between quality and effect sizes varied for individual quality criteria across datasets primarily due to results in dataset 2 (EPC reports). Most consistent results were shown for allocation concealment: across datasets, concealed trials reported smaller effect sizes compared to unconcealed trials.

Applying a quantitative summary score, a cut-off of 6 met criteria differentiated studies best across three out of four datasets (i.e., the difference between low and high quality studies was most distinct); however, this effect could not be found for dataset 3 (the EPC reports). In only one of the datasets (Dataset 1 Back pain) was the difference statistically significantly different.

The figure (Figure 8) allows a graphic overview for the CBRG criteria across the four epidemiological datasets that we compiled in the course of the project.

Figure 8 Associations between CBRG criteria and reported treatment effects across datasets

CBRG = Cochrane Back Review Group; ITT = intention to treat

Note: From left to right: dataset 1 (Back pain trials), dataset 2 (EPC reports), dataset 3 (‘Pro-bias’, fixed-effects model), dataset 4 (“Heterogeneity set”)

Figure 8 allows a comparison of the forest plots displaying the differences in effect sizes of low and high quality studies for all 11 quality criteria. Datasets 1, 3, and 4 shows fairly consistent associations across the 11 datasets with lower quality studies reporting larger effect sizes, however, dataset 2 (EPC reports) shows different results compared with the other datasets.

Results are based on effect size differences in the first two datasets and on the ratio of odds ratios in dataset 3 and 4. In addition, the 95 percent confidence interval for the effect is shown. The direction of effects is displayed consistently across datasets—point estimates on the left indicate that low-quality studies reported larger treatment effects.

### Heterogeneity and Effect Size Distributions

The different datasets comprise individual meta-analyses, each of which contributes trials to the total dataset. The following table (Table 8) shows the amount of between-study variance in effect sizes expressed as I^2^. In addition, the I^2^ of the entire dataset is shown.

Table 8 Heterogeneity

Interventions | # Studies | Pooled RE ES | I^2^
Dataset 1: Back Pain
Acupuncture | 17 | 0.45 | 71.5%^*^
Back School | 14 | 0.40 | 68.6%^*^
Behavior Therapy | 18 | 0.62 | 28.9%
Exercise Therapy | 45 | 0.58 | 68.1%^*^
Manipulation | 23 | 0.50 | 62.1%^*^
Muscle Relax | 23 | 0.53 | 85.3%^*^
NSAID | 33 | 0.39 | 70.7%^*^
Other | 43 | 0.51 | 8.9%
Overall | 216 | 0.50 | 72.4%^*^
Dataset 2: EPC Reports
Alzheimer’s | 14 | 0.50 | 26.2%
Arthritis | 3 | 1.45 | 99.4%^*^
CDSM | 19 | 0.34 | 49.7%^*^
Chromium | 6 | 0.41 | 84.6%^*^
Epilepsy | 25 | 0.52 | 52.7%^*^
Glucosamine | 20 | 0.37 | 71.7%^*^
OCD | 9 | 0.95 | 98.2%^*^
Omega 3 | 17 | 0.04 | 57.0%^*^
Orlistat | 17 | 0.47 | 65.2%^*^
S-AMe | 11 | 0.62 | 69.1%^*^
SMBG | 10 | 0.14 | 33.5%
Vitamin E | 14 | 0.10 | 51.9%^*^
Overall | 165 | 0.43 | 97.5%^*^
Dataset 3: Pro-bias
Dolan | 11 | 0.49 | 74.1%^*^
Hughes | 3 | 0.90 | 0.0%
Lensing | 5 | 0.19 | 0.0%
Loonen | 9 | 0.25 | 0.0%
Loosemore | 6 | 0.37 | 49.7%
Mari | 5 | 0.19 | 0.0%
Marshall | 5 | 0.11 | 48.9%
Pace | 22 | 0.35 | 48.5%^*^
Ramirez | 10 | 0.88 | 0.0%
Sandercock | 9 | 1.67 | 3.9%
Sutherland | 15 | 0.83 | 52%^*^
Overall | 100 | 0.46 | 59.6%^*^
Dataset 4: Heterogeneity set
Ausejo | 5 | 0.59 | 88.3%^*^
Bhuta | 6 | 0.32 | 72.7%^*^
Kellner | 8 | 0.26 | 61.8%^*^
Kozyrskyj | 27 | 1.08 | 31.0%
Rosenfield | 10 | 0.32 | 77.9%^*^
ATC | 10 | 0.89 | 16.0%
Hine | 10 | 1.28 | 32.4%
Leizorovicz | 11 | 0.78 | 39.1%
Yusuf – Beta-blocker | 13 | 0.8 | 41.4%
Yusuf - Streptokinase | 28 | 0.76 | 0.0%
Yusuf - Nitrates | 8 | 0.67 | 41.7%
Rossouw | 7 | 0.82 | 24.1%
Teo | 6 | 0.31 | 31.0%
Overall | 149 | 0.75 | 60.0%^*^

ATC = Antiplatelet Trialists’ Collaboration; CDSM = chronic disease self-management; I^2^ = amount of between-study variance in effect sizes; OCD = obsessive-compulsive disorder; NSAID = non-steroidal anti-inflammatory drugs; RE ES = effect size (random effects meta-analysis); RE OR = odds ratio (random effects meta-analysis);

S-AMe: = S-adenosylmethionine; SMBG = self-monitoring of blood glucose

* p<0.05, chi-square test.

The amount of heterogeneity in dataset 1 estimated by I^2^ ranged from 8.9 to 85.3 percent in individual trials. The overall estimated heterogeneity for the entire dataset was 72.4 percent.

In dataset 2, the EPC reports, individual I^2^ estimates were generally higher and ranged from 26.2 to 99.4 percent and the overall dataset estimate was 97.5 percent.

Several meta-analyses in dataset 3 (Pro-bias) showed no evidence of heterogeneity; the overall dataset heterogeneity estimate was 59.6 percent.

Dataset 4 showed some heterogeneity, but some estimates were not statistically significant and the overall database estimate was 60 percent. The overall estimate was not higher but comparable to dataset 1 and 3, although heterogeneity across studies was one of the inclusion criteria for the selection of meta-analyses that were compiled for this dataset.

#### Dataset Distributions

The effect size distributions varied across meta-epidemiological datasets that we assembled in the course of the project. In particular, the effect size distribution in one of the datasets (Dataset 2, EPC reports) was less symmetric (bell-shaped) than those of the other datasets. The figure below (Figure 9) shows the distribution of the effect sizes reported for each included study in this dataset.

Figure 9 Dataset 2 distribution

EPC = Evidence Based Practice Center

Figure 9 is a histogram showing the skewed effect size distribution of dataset 2 (EPC reports) that was reported in a previous report.

As previously reported, the mean treatment effect across all studies in this dataset was 0.43 (95% CI: 0.34, 0.53). Few quality features were associated with differences in effect sizes according to whether these criteria were met. The table (Table 9) shows the effect sizes for studies meeting the particular criterion and studies not meeting the criterion in dataset 2 (EPC reports) as previously published. The last column shows the difference between studies that met and did not meet criteria. A negative difference indicates that the effect size for the studies fulfilling the criterion was smaller than the effect size for the studies not meeting the criterion.

Table 9 Dataset 2 results associations between quality and effect sizes

CBRG Criteria | ES Criterion met | 95% CI Criterion met | ES Criterion not met | 95% CI Criterion not met | ESdiff | 95% CI
Randomization adequate | 0.44 | (0.30, 0.57) | 0.43 | (0.34, 0.51) | 0.01 | (-0.15, 0.17)
Allocation concealment | 0.39 | (0.25, 0.53) | 0.45 | (0.36, 0.53) | -0.05 | (-0.22, 0.11)
Similar baseline | 0.40 | (0.31, 0.49) | 0.49 | (0.37, 0.61) | -0.09 | (-0.24, 0.05)
Assessor blind | 0.43 | (0.36, 0.51) | 0.37 | (0.04, 0.71) | 0.06 | (-0.28, 0.41)
Care provider blind | 0.48 | (0.40, 0.56) | 0.29 | (0.15, 0.43) | 0.19 | (0.03, 0.35)^*^
Patient blind | 0.47 | (0.40, 0.55) | 0.26 | (0.11, 0.42) | 0.21 | (0.04, 0.39)^*^
Acceptable dropout rate | 0.50 | (0.40, 0.59) | 0.35 | (0.24, 0.45) | 0.15 | (0.01, 0.29)^*^
Original group (ITT) | 0.45 | (0.36, 0.54) | 0.40 | (0.27, 0.52) | 0.05 | (-0.10, 0.20)
Similar co-interventions | 0.44 | (0.36, 0.52) | 0.39 | (0.20, 0.58) | 0.05 | (-0.15, 0.28)
Acceptable compliance | 0.44 | (0.34, 0.55) | 0.42 | (0.32, 0.52) | 0.02 | (-0.12, 0.17)
Similar timing | 0.44 | (0.37, 0.51) | 0.19 | (-0.24, 0.62) | 0.25 | (-0.19, 0.69)
Summary Score
≥6 vs <6 | 0.46 | (0.38, 0.53) | 0.30 | (0.12, 0.47) | 0.16 | (-0.03, 0.35)
≥5 vs <5 | 0.45 | (0.38, 0.53) | 0.18 | (-0.06, 0.42) | 0.27 | (0.02, 0.52)^*^

CBRG = Cochrane Back Review Group; CI = confidence interval; ES = effect size; ESdiff = effect size difference;

ITT = intention to treat

* p<0.05

The results show that for only two criteria (allocation concealment and baseline similarity), lower-quality studies reported larger effect sizes than higher-quality studies. The other criteria showed no effect or the opposite effect, the quantitative summary score that statistically significantly differentiated high- and low-quality studies in other datasets showed no significant effect, and the direction of the effect trend was reversed.

As outlined in the methods section, we wanted to investigate whether the distribution characteristics are correlated with the difference in associations between quality and effect sizes; hence we used a non-parametric sampling approach to mirror the distribution of dataset 2 in other datasets. The following histogram (Figure 10) shows dataset 1 using dataset 2 effect sizes.

Figure 10 Dataset 1 using dataset 2 effect sizes

Figure 10 is a histogram showing dataset 1 using dataset 2 effect sizes with the outlined sampling strategy. The histogram shows that the sampling method was successful in creating a similar distribution shape.

The histogram shows that the sampling method was successful in creating a similar distribution shape.

In a further step, we investigated how the association between quality and effect sizes would be affected by this process. The table below (Table 10) shows the associations between quality features and effect sizes based on these specifications. To allow a direct comparison, the table displays the new results as well as the original research results as published previously. Differences between high- and low-quality studies (defined as meeting a particular criterion or not) were expressed as effect size differences. A negative difference indicates that the group of studies not meeting the quality criterion reported larger effect sizes than the group of studies that met the individual criterion.

Table 10 Effect size difference comparison dataset 1

CBRG Criteria | New ESdiff | New 95% CI | Original ESdiff | Original 95% CI
Randomization adequate | 0.14 | (-0.01, 0.28) | 0.02 | (-0.12, 0.16)
Allocation concealment | -0.02 | (-0.17, 0.13) | -0.08 | (-0.23, 0.07)
Similar baseline | -0.03 | (-0.18, 0.12) | -0.10 | (-0.24, 0.05)
Assessor blind | 0.09 | (-0.05, 0.24) | -0.10 | (-0.25, 0.04)
Care provider blind | 0.07 | (-0.09, 0.22) | -0.10 | (-0.26, 0.06)
Patient blind | 0.05 | (-0.09, 0.20) | -0.03 | (-0.18, 0.11)
Acceptable dropout rate | 0.05 | (-0.11, 0.20) | -0.13 | (-0.29, 0.02)
Original group (ITT) | -0.08 | (-0.23, 0.06) | -0.10 | (-0.24, 0.04)
Similar co-interventions | 0.00 | (-0.15, 0.14) | -0.09 | (-0.23, 0.05)
Acceptable compliance | -0.02 | (-0.16, 0.13) | -0.01 | (-0.15, 0.14)
Similar timing | -0.13 | (-0.41, 0.15) | -0.17 | (-0.43, 0.10)
Summary Score
≥6 vs <6 | -0.02 | (-0.17, 0.12) | -0.20 | (-0.34, -0.06)^*^
≥5 vs <5 | 0.08 | (-0.08, 0.23) | -0.20 | (-0.35, -0.05)^*^

CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat

* p<0.05

The table shows that dataset 1, which had originally shown consistent effects of quality by indicating that lower quality studies exaggerated treatment effects, now shows conflicting results. Some criteria were associated with effect sizes, some were not, and the direction of effects varied across effect sizes.

To investigate whether this observation could be replicated in another dataset, we applied the process to dataset 3 (Pro-bias). This dataset was a replication of parts of a larger dataset that had shown clear effects of quality in previous investigations (Moher et al., 1998). The following histogram (Figure 11) shows dataset 3 using dataset 2 effect sizes.

Figure 11 Dataset 3 using dataset 2 effect sizes

Figure 11 is a histogram showing dataset 3 using dataset 2 effect sizes. The histogram shows that the sampling process was also successful in replicating a distribution that resembled the original distribution of dataset 2.

The histogram indicates that the sampling process was also successful in replicating a distribution that resembled the original distribution of dataset 2.

The table below (Table 11) shows the associations between quality features and effect sizes based on these specifications and also lists the original effects. The original results are reported as the ratio of odds ratios between high- and low-quality studies, whereas the new results are shown as effect size differences since the sampled dataset was based on continuous outcomes. A negative effect size difference means that the group of trials meeting the criterion reported smaller treatment effects than the group of trials not meeting the criterion. A ROR less than one also indicates that studies meeting the criterion reported smaller treatment effects than studies not meeting the criterion.

Table 11 Effect size difference comparison dataset 3

CBRG Criteria | New ESdiff | New 95% CI | Original ROR | Original 95% CI
Randomization adequate | -0.13 | (-0.32, 0.07) | 1.05 | (0.69, 1.60)
Allocation concealment | -0.03 | (-0.23, 0.18) | 0.88 | (0.56, 1.39)
Similar baseline | -0.08 | (-0.27, 0.11) | 1.40 | (0.92, 2.12)
Assessor blind | -0.01 | (-0.23, 0.21) | 1.55 | (0.95, 2.51)
Care provider blind | -0.08 | (-0.27, 0.11) | 1.02 | (0.66, 1.57)
Patient blind | -0.14 | (-0.34, 0.06) | 1.20 | (0.77, 1.87)
Acceptable dropout rate | -0.08 | (-0.27, 0.10) | 0.83 | (0.57, 1.22)
Original group (ITT) | -0.06 | (-0.27, 0.14) | 1.00 | (0.65, 1.52)
Similar co-interventions | 0.03 | (-0.17, 0.23) | 1.51 | (1.00, 2.27)^*^
Acceptable compliance | 0.01 | (-0.17, 0.20) | 0.70 | (0.47, 1.03)
Similar timing | 0.06 | (-0.22, 0.34) | 1.35 | (0.71, 2.58)
Summary Score
≥6 vs < | -0.18 | (-0.36, 0.01) | 0.99 | (0.66, 1.49)
≥5 vs < | -0.11 | (-0.32, 0.09) | 1.05 | (0.66, 1.67)

CBRG = Cochrane Back Review Group; CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat; ROR = ratio of odds ratios

* p<0.05

The difference between the original data and the new data was less clear in this dataset. This finding may in part be due to inconsistencies across quality criteria that was apparent in the original data—while the majority of criteria trials not meeting criteria overestimated treatment effects, this effect was not shown for all criteria—and in part due to the fact that it is difficult to compare ratios of odds ratios and effect sizes.

## Monte Carlo Simulations

We report simulations for three different sets of parameters. The parameters selected closely resemble realistic effects observed in previously obtained empirical datasets.

### Dataset 1 (Back Pain Dataset Specifications)

The first analysis used the characteristics observed in dataset 1 (Back pain). This dataset included 216 individual trials with a mean sample size of 80. The observed difference between effect sizes of trials that did and did not attain a quality criterion ranged from 0.02 (adequate randomization) to -0.17 (similar timing), with most criteria indicating that lower-quality studies reported larger treatment effects, thereby exaggerating treatment effects compared to higher-quality studies. The difference, applying the summary score in effect size between low- and high-quality studies was 0.20 (van Tulder et. al., 2009).

We systematically varied the effect of quality and set it to be 0.1 or 0.2 (standardized effect size difference between high-and low-quality trials). We varied the amount of heterogeneity present in the dataset and such an additional variance parameter of 0.14 was used (giving an I^2^ that matched the sample of 72.4 percent), a variance parameter set to half of that value, or a variance parameter of zero. The table (Table 12) shows the effect of these specifications on the power.

Table 12 Power to detect quality moderator effects determined by Monte Carlo simulation under varying effects of quality and heterogeneity, with simulation parameters matching dataset 1 (Back pain trials)

Quality Effect | Additional Variance = 0.14 | Additional Variance = 0.07 | Additional Variance = 0.00
Median I^2^* | 72.4 | 55.5 | 0.00
Median τ^2^** | 0.13 | 0.07 | 0.00
Quality effect = 0.1 | 0.38 | 0.50 | 0.85
Quality effect = 0.2 | 0.91 | 1.00 | 1.00

* Observed heterogeneity (I-squared)

** Observed heterogeneity (tau-squared)

In this simulation, the power to detect quality effects as large as 0.2 was found to be high (0.91) in datasets that replicated the heterogeneity of dataset 1 (Back pain): Note that the distribution of quality was set up to ensure the maximum power to detect that effect. For smaller quality effects (0.1), power was considerably lower when heterogeneity was high. As heterogeneity decreased, the power to detect effects increased. With no additional heterogeneity (i.e. assumptions of a fixed-effects model being true), the power to detect a quality effect of 0.1 was acceptably high (0.85).

### Dataset 2 (EPC Reports Dataset Specifications)

A further dataset, the EPC reports, was the basis of another set of simulations. This dataset contained 165 individual trials with a mean sample size of 286. The level of heterogeneity found in this study was very high (97.5 percent). The treatment effect was approximately 0.5. In the empirical dataset, study quality showed no consistent effect and several unexpected results in that lower study quality was associated with smaller reported treatment effects compared to higher-quality studies. The effect size differences ranged from -0.09 to 0.25.

The table (Table 13) shows the effects of three different levels of quality on power, assuming three different levels of heterogeneity. Again, the effect of quality was set at 0.1 or 0.2. An additional variance parameter of 0.70 was required to match the sample I^2^ of 97.5, and 0.35 was used for half variance.

Table 13 Power to detect quality moderator effects determined by Monte Carlo simulation under varying effects of quality and heterogeneity, with simulation parameters matching dataset 2 (EPC reports)

Quality Effect | Additional Variance = 0.70 | Additional Variance = 0.35 | Additional Variance = 0.00
Median I^2^* | 97.5 | 95.5 | 0.00
Median τ^2^** | 0.61 | 0.32 | 0.00
Quality effect = 0.1 | 0.12 | 0.20 | 1.00
Quality effect = 0.2 | 0.37 | 0.60 | 1.00

* Observed heterogeneity (I-squared)

** Observed heterogeneity (tau-squared)

In this dataset, the power to detect effects of quality was low, when the effects of quality were 0.2. When heterogeneity was reduced, the power increased, although even with half the additional variance power was still lower than ideal, at 0.6. When there was no additional unexplained heterogeneity power was very high. This dataset contained a larger number of trials, with large sample sizes, which further increase the power to detect quality effects, hence the high power when heterogeneity is low.

### Dataset 3 (Pro-bias Dataset Specifications)

The final simulations were based on the Pro-bias dataset, dataset 3. This dataset contained 100 trials with a mean sample size of 119. Between-study variance was moderate, with I^2^ of approximately 60 percent. In the empirical dataset, the effect of study quality ranged from 0.01 to 0.25. As before, we investigated setting the quality moderator effect to 0.1 or 0.2. An additional variance parameter of 0.05 was used, matching the value of I^2^ in the empirical dataset (Table 14).

Table 14 Power to detect quality moderator effects determined by Monte Carlo simulation under varying effects of quality and heterogeneity, with simulation parameters matching dataset 3 (‘Pro-bias’)

Quality Effect | Additional Variance = 0.05 | Additional Variance = 0.025 | Additional Variance = 0.00
Median I^2^* | 59.6 | 44.8 | 0.00
Median τ^2^** | 0.05 | 0.03 | 0.01
Quality effect = 0.1 | 0.42 | 0.58 | 0.73
Quality effect = 0.2 | 0.92 | 0.99 | 1.00

* Observed heterogeneity (I-squared)

** Observed heterogeneity (tau-squared)

In a dataset with these specifications, the power to detect quality effects was acceptable when the quality effect was as high as 0.2, however, for smaller quality effects, the power was reduced. Again, with reduced heterogeneity, the power increases, although even with zero additional heterogeneity, the power to detect a quality effect of 0.1 still does not reach generally acceptable levels.